# Implications for Researchers

## Assessing Health-Related Quality of Life

As Feinstein suggested, “assessments of health status are important because improvements in symptoms, other clinical problems, and functional capacity are usually the main goals of patients in seeking clinical care”.105 Similarly, Osoba and King argue that “the ultimate goal of health care is to restore or preserve functioning and well-being related to health, that is health-related quality of life.”106 These ideas are underscored in the Public Comment Draft Report of the Patient-Centered Outcomes Research Institute Methodology Committee presented on July 23, 2012 (www.pcori.org/2012/methodology-report/).

Studies investigating ways to improve or maintain functional status in older adults need to include the assessment of HRQL. But using which measures? Generic measures provide the basis for broad comparisons, the ability to reflect comorbidities, and the ability to detect side effects and other consequences. More targeted measures often focus on the most salient domains and are often more responsive than generic measures.

One criterion in guiding the choice of and mix of type of measures should be the availability of evidence on the reliability, construct validity, and responsiveness of the measure in the context in which it will be applied. Sometimes there is a tension between choosing measures with well documented measurement properties in that application and choosing widely-used measures that permit comparison to other studies.

There is, however, a risk of “premature” standardization.107,108 For instance, if a widely-used generic measure is chosen to enhance the ability to make comparisons to other studies, but that generic measure has inferior measurement properties relative to some other generic measures in the relevant area of application, then neither internal validity nor external generalizability are well served. Measures need to be chosen on the basis of relevance and their track record in the context of the study at hand. Further, as the examples presented in the paper illustrate, in general scores and change scores among generic measures are not interchangeable.

Studies of older adults must attend to these multiple challenges. Inclusion and exclusions criteria need to match the level of vulnerability of study participants appropriate for an intervention. Interventions need to be systematized and reproducible. Control and intervention groups must reflect the variability of health trajectories in older people (no easy task, as this is infrequently known at the start of a trial). Multiple inter-related outcomes need to be considered. Measures need to be appropriate for the baseline population to avoid floor and ceiling effects. Comparability across studies would be enhanced if researchers were to agree on a small number of measures that are appropriate for older populations. Examples of such efforts include Core Outcome Measures for Effectiveness Trials initiative (www.comet-initiative.org) and Outcome Measures in Rheumatology Trials (www.omeract.org). MIDs should be determined beforehand in a study.

Systematically adding measures of HRQL and functional status to studies of older adults and the routine use of these measures in chronic care management would importantly add to the evidence available.84,109,110 In particular, routine collection would provide evidence on persons seldom included in clinical trials, such as patients with multiple chronic conditions, concomitant medications, and older adults.111,112 The use of health profile measures and measures of symptom or function from the Patient Reported Outcomes Measurement Information System (PROMIS) has the potential to enhance the ability to make focused comparisons across populations and studies (www.nihpromis.org).113-115 Of course, substantial evidence on the measurement properties of PROMIS measures in older adult population will be required before those measures can be recommended. The usefulness of adding HRQL assessments to studies and registries would be enhanced by adherence to reporting standards for HRQL evidence.116-120

An additional very important criterion in selecting measures for use in older adult populations is evidence of their acceptability to respondents, family members, and clinicians.15 In particular Haywood and colleagues report that measures acceptable to general adult populations are sometimes not acceptable to older respondents.43