# Peer Reviewers

- Mary Butler, Ph.D., M.B.A.
  Division of Health Policy & Management
  School of Public Health
  University of Minnesota
  Minneapolis, MN
- Kirstie L. Haywood, D.Phil.
  Senior Research Fellow (Patient Reported Outcomes)
  Royal College of Nursing Research Institute
  School of Health and Social Studies
  University of Warwick
  Coventry, United Kingdom
- Christine McDonough, Ph.D., P.T.
  Research Assistant Professor
  Health & Disability Research Institute
  Department of Health Policy and Management
  Boston University School of Public Health, Boston University
  Boston, MA
- Mari Palta, Ph.D.
  Professor of Population Health Sciences and of Biostatistics and Medical Informatics
  Department of Population Health Sciences
  School of Medicine and Public Health
  University of Wisconsin–Madison
  Madison, WI
- Kathleen W. Wyrwich, Ph.D.
  Senior Research Leader
  Evidera
  Bethesda, MD