# Acknowledgments

The authors thank Dr. Gordon H. Guyatt, Dr. David B. Reuben, Dr. Jennifer Lin, Dr. Ron Klein, Dr. Tracy Wolff, Dr. Erica S. Breslau, Dr. Elliot J. Roth, Dr. Robert Kane, and participants in the Research In Progress Seminar Series, Division of General Internal Medicine and Geriatrics, Oregon Health & Science University, June 1, 2010, for their constructive comments and suggestions on the work reported here. Further, the authors thank Tracy Beil, Jill Pope, Heather Baird, and Debra Burch for their assistance with the preparation of the manuscript.