# Measurement Properties

Table 1 Brief review of evidence on measurement properties for generic measures and selected disease-specific measures frequently used to assess health status and health-related quality of life in the older adults*