# Results

## Existing Literature on Improving the Use of Systematic Reviews To Inform Study Designs

We identified several studies, which have attempted to provide frameworks or conceptual models in order to improve the use of systematic reviews (SRs) in the design of future research studies, as well as additional material of relevance to our aim.

A series of eight Future Research Needs (FRN) projects funded by the Agency for Healthcare Research and Quality have aimed to propose new methods and tools for identifying and prioritizing research gaps using SRs. The eight documents address different aspects of identification of research gaps. These were intended to be used both by systematic reviewers, new researchers, and funders to improve the efficiency of evidence generation. Of the existing FRN methods studies, the most pertinent to the current proposal is “Frameworks for Determining Research Gaps.”18 The authors of this study contacted all the Evidence-based Practice Centers and various other organizations around the world to develop a framework to identify and categorize the evidence gaps from SRs. The proposed framework tool characterizes the gaps using the PICOTS (populations, interventions, comparators, outcomes, timing and setting) elements and identifies the reasons by using the following four categories:

1. Insufficient or imprecise information
2. Biased information
3. Inconsistency or unknown consistency
4. Not the right information.

This framework provides a useful method for identifying and characterizing evidence gaps from SRs, and we draw on its findings in the current project. It differs from the current study in that its focus is primarily from the perspective of systematic reviewers, rather than clinical researchers proposing new studies.

Sutton et al.27 proposed a conceptual model with the intention of “making better use of information contained within the existing evidence base when designing future studies, and maximizing the information so gained and thus potentially reducing the need for future RCTs.” Their framework depends on the existence of a current SR and meta-analysis, and proposes several ways that evidence synthesis models can potentially be applied to existing data in these meta-analyses. These might include using individual patient data meta-analyses to address uncertainty in population subgroups and mixed treatment comparison modeling to synthesize competing interventions. Their framework suggests that further trials should only by conducted when these advanced synthesis methods do not provide a conclusive answer, and that the design of such trials should be based on the existing evidence. However, the latter focuses several methods to estimate the power of a new trial based on the results of the existing meta-analysis, either in isolation or to update the existing meta-analysis. The limitations of this framework are that it focuses only on the quantitative findings from meta analyses, implies the need for meta analyses for the application of advanced synthesis methods, and does not provide guidance about how existing trials can be used to inform design of further studies aside from power and sample size.

Several publications have proposed methods which can be used to simulate sample size calculations and power calculations, based the findings from existing meta-analyses.28 We identified several articles which outlined various models that can be used by statisticians to provide more accurate estimates in the design phase of new trials.5, 29 We also examined the literature on value of information (VOI) also known as value of research studies which attempt to provide a systematic approach to informing the optimal design of research studies and their prioritization.30 These models calculate the probability that research would provide evidence for an improved treatment decision and the gains that are to be expected from this improved treatment decision.31 Such VOI studies have been used to justify the importance of proposed studies, and can compare study designs in terms of net benefit given the costs of studies. Although a minimal modeling approach to using VOI has been proposed, we considered that these approaches would be too complex for most clinical researchers, given the decision analytic modeling involved.21

We also identified principles which had originally been developed to help systematically assess applicability of an SR for informing practice and policy.25 This study suggested a framework for identifying and organizing the details of the PICOTS elements which need to be examined in detail in order to assess applicability. However, this framework was not designed for use by clinical researchers proposing new studies.

## Proposed Four-Step Framework

The four-step process for researchers who are in the design phase of study proposal or protocol writing is outlined in the Figure 1. Step 1 involves laying out the crucial design elements of the proposed study using PICOTS elements. Step 2 uses a simple method to identify an existing SR which is current, valid and relevant enough to the proposed research study to inform its design. In Step 3, the details of the SR are examined to determine the extent to which it has already addressed the questions proposed by the new study, and identifies the PICOTS elements of the primary studies included in the SR which can be used to modify the design of the proposed study. Finally, Step 4 establishes the need (or otherwise) for the proposed study, and prioritizes modifications to research design based framework.

Figure 1 Proposed four-step framework

PICOTS = populations, interventions, comparators, outcomes, timing, and setting

The figure illustrates the steps in the proposed four-step framework, which are, Step 1) outline the PICO of the proposed new study; Step 2) identify a relevant, valid, and current systematic review; Step 3) use the body of evidence from the systematic review to inform the proposed new study; and Step 4) summarize implications for the proposed new study.

### Step 1 Outline the PICOTS of the Proposed New Study

For all trials of interventions, the key questions can be described using the PICOTS elements, which include patient group, intervention, control or comparators, outcomes of the study (main or important ones), timing (or duration of follow-up), and study design. (Box 1). Therefore the aim of Step 1 is to clearly delineate these basic elements, in addition to other study characteristics, and lay out each component discretely. Some trials will have several interventions (e.g. different medications, different doses), and most trials will have multiple outcomes. The reason for outlining each of the PICOTS elements is to facilitate all subsequent phases of the proposed framework, where the PICOTS of the proposed study will be compared with SRs, and then with the body of evidence identified from the SR.

Box 1 Outlining the main elements of a proposed study

1. Patient group
2. Intervention
3. Control or comparator
4. Outcomes (main/important outcomes)
5. Timing (duration of followup)
6. Setting
7. Study design

### Step 2 Identify a Relevant, Valid, and Current Systematic Review

The aim of Step 2 is to identify one (or more) existing SR which is sufficiently relevant, valid, and current in relation to the proposed research study and assess its internal validity and whether it is current. The process of searching and retrieval of SR is well established, and researchers have access to numerous free search engines (e.g., TRIP, Pub Med, etc), which for most research institutions will then provide full text online access to identified SRs. In some cases, information specialists may improve the efficiency and success of searches for SRs.

For some clinical questions, there may be no SR available. If the researcher is aware of or identifies a large body of primary studies which have not be summarized into a SR, we suggest that a formal SR may be a greater priority than embarking on a primary research study.

#### A Is It relevant?

Identifying a SR that is sufficiently relevant to the proposed research study involves initially examining only the title and/or abstract of SRs identified by a search to allow those that are clearly irrelevant to be immediately discarded. Then, a more detailed assessment of the abstract and if necessary full text of SRs can be used to identify one (or more) which is sufficiently similar or relevant to the proposed research study.

There is no quantitative or objective way to assess the relevance of a SR in relation to a proposed research question; this is inevitably a subjective decision. If too narrow relevance criteria are applied then it might be impossible to identify any qualifying SR, while if criteria are too broad then SRs with very limited relevance may be identified and be of little value to the researcher.

We therefore suggest a pragmatic approach by comparing the PICOTS elements from the SRs to those from the proposed study. For researchers the key question is whether the SR is relevant enough (or similar enough) to their proposed research question. For some clinical areas where there are numerous SR of interventions it will be possible (and necessary) to be more selective and attempt to find a SR that matches on several PICOTS elements. In other clinical areas where there are fewer SRs it will be necessary to be more inclusive, and include for example a SR that “matches” on only patient group and intervention.

Assessing whether a SR is relevant can usually be achieved by looking at the aims and methods (in particular inclusion and exclusion criteria) of the SR. It is not necessary for the researcher to examine the findings of the SR at this stage. Box 2 is intended to facilitate this process: the PICOTS elements from the proposed study (i.e., those already outlined in Step 1) are compared with the corresponding elements obtained from methods section of the SR.

Box 2 Assessing relevance of a SR for the proposed study

1. Patient group in the SR: Are they relevant to proposed study?
2. Intervention(s) in SR: Are they relevant to proposed study?
3. Control or comparator in the SR: Are they relevant to proposed study?
4. Outcomes (main/important outcomes) in the SR: Are they relevant to proposed study?
5. Timing (duration of followup) in the SR: Are they relevant to proposed study?
6. Setting in the SR: Are they relevant to proposed study?
7. Study design in the SR: Are they relevant to proposed study?

For some proposed research questions, there may be no relevant SRs identified. In these cases it may be valuable to broaden the search criteria and conduct another cycle of searching and assessment.

#### B Is It Valid?

Even if a SR appears sufficiently relevant to the proposed research study, it is important to critically appraise key areas of its internal validity in order to determine whether its findings are likely to be biased.

There are multiple possible elements of internal validity (or methodological quality) that can be assessed in SRs, and multiple tools have been proposed to facilitate their appraisal including several checklists.10 Another pragmatic appraisal tool that was developed by the Centre for Evidence-Based Medicine (Box 3) is available for clinicians.32 It assesses the four main areas of internal validity of SRs: comprehensiveness of literature search, criteria used to select articles, sufficient validity of included studies, and similarity of included studies.

Box 3 Assessing internal validity of an existing SR

1. Comprehensiveness of literature search
2. Criteria used to select articles
3. Included studies of sufficient validity and quality
4. Similarity, or degree of homogeneity, of included studies

The sections of the SR which a researcher needs to look at in order to assess the elements of internal validity, will include the methods section to identify the search strategy and inclusion and exclusion criteria; the results section to examine the characteristics of included studies to assess the similarity (i.e., homogeneity/heterogeneity) of included studies; where meta-analyses have been performed; and the statistical measures of heterogeneity.33

Having identified these elements, it is necessary for the researcher to assess their impact on the validity of the SR and its findings. This is a subjective process. If the SR lacks sufficient internal validity, then it may not be possible to trust its findings and it should not be used to further inform the design and conduct of the proposed study.

#### C Is It Current?

The search date of the SR identified indicates how current the SR is. There is no objective period of time beyond which all SR require updating. Guidelines for example are generally considered out of date after 5 years, while the interval for updating reviews median duration of time before signals that the evidence had changed was 5.5 years (but was as short as 2 years for some clinical areas).34 Assessing how current a SR is depends on the clinical topic—if this is likely to be changing rapidly, then a very recent search date is important, whereas for other clinical areas, a less current SR is likely still to be of value.

If there is sufficient uncertainty regarding whether the SR identified is sufficiently current for the proposed research topic, then an information specialist can be used to search for articles published between the last date of search of the SR and the present day. If this search indicates that there are potentially additional primary research papers, the researcher may consider their impact on the existing SR and whether it needs updating.

### Step 3 Use the Body of Evidence Assessed in the Systematic Review To Inform the Proposed Research Study

#### A What can be Learned From the Primary Studies Included in the Systematic Review?

The aim of this step is to assess whether the design of the proposed study should be modified based on the details of the study designs of previous studies, and in what ways (Box 4). Identifying similarities as well as differences of the studies included in the SR to the proposed research study may be useful. Similarities between the proposed study and the primary studies included in the SR may reinforce the importance of such design features for the proposed study. Differences however may serve to highlight features where the researcher may have to justify/explain such differences and whether or not their study design should be modified. The researcher can use these to inform design of the proposed study by justifying why proposed PICOTS elements are different from those in primary studies, gaining new information on PICOTS elements that were not known to the researcher previously, and highlighting gaps in the existing primary studies which the proposed study aims to address.

Box 4 Comparing the details of the primary studies and the proposed study

1. Patient group: Compare details of planned included population, eligibility, and exclusion criteria.
2. Intervention: Compare details of planned intervention in terms of type, dose, intensity, delivery of intervention, monitoring of intervention, presence of cointerventions, feasibility in planned settings, and run-in periods.
3. Control or comparators: Compare similarity of placebo planned and description of standard care.
4. Main/important outcomes: Compare primary and secondary outcomes, short term or surrogate outcomes, composite outcomes, and clinically relevant outcomes.
5. Duration of followup: Compare details of duration and process for followup and linearity of outcome with time (i.e. fewer measures may be needed).
6. Setting: Compare details of setting (primary and secondary care, etc.)
7. Study design: Compare study designs, sources of bias of included studies, feasibility of study designs higher in hierarchy, sample sizes and power calculations used, and feasibility of using data to assist with simulation for proposed study sample size or power calculations.

For most SRs this information can be identified in the results sections where there is a narrative description of included studies, or can be found in the “characteristics of included studies” tables.

#### B What Does the SR Answer and Where Do Gaps Remain?

This step examines the quantitative findings from the body of evidence included in a SR selected in the previous step, to determine the extent to which it answers some or all of the questions/aims of the proposed study, and where gaps still remain. In order to find this information, the researcher will need to examine the Results section of the review identified in the above steps.33

The key goal of this step is first to assess whether or not the SR has explicitly addressed a stated outcome/aim (or more than one outcome/aim) of the proposed research study, and if so what were the findings. There are two possible scenarios:

1. Proposed study question has been answered adequately by the SR. In this case the aim of the proposed research study has been answered adequately by the SR. Adequately implies an effect size which demonstrates evidence of effect (or lack of effect), an effect that is clinically significant, and one where there is sufficiently narrow confidence interval. When the SR identifies a high quality of evidence and adequately answers the aims of the proposed study, there may be little justification for a further trial of efficacy. Rather, study designs which focus on implementation, translation, or dissemination may be of greater priority.
2. Proposed study question has not been answered adequately by the SR. In this case, the aim/outcome of the proposed research study has not been answered adequately by the SR, or has only been answered partially. “Inadequately” could mean the outcomes/aims of the SR are not similar enough to that proposed by the new research study, there is insufficient evidence of effect (or no evidence of lack of effect), there are wide confidence intervals, or there is an effect which is not clinically significant. The body of evidence of the SR can then be examined to identify explanations for the inability of the SR to answer the proposed study question. These can be grouped into four main categories (Box 5).18

Box 5 Reasons for failure of SR to address proposed study question

1. Insufficient data: too few primary studies, or studies that are too small (sample size inadequate or not adequately powered)
2. Imprecise data: insufficient evidence of effect or lack of effect
3. Potentially biased information: primary studies were of inadequate quality to address the question
4. Inconsistency: effect sizes from different studies go in different directions, or there are large differences between the effect sizes of different studies.

### Step 4 Summarize Implications for the Proposed New Study

The aim of the final step is to summarize the findings from the previous step and provide an overall decision on the need for the proposed study and the ways in which its design may be modified based on the SR. The interpretation of the findings from this step once again requires the insight of the researcher (and funder of proposed study) in terms of the overall need for the proposed study and the modifications that could be made to the proposed study design and rationale.

1. In what ways does the proposed research study address the gaps in the evidence identified by the SR?
2. Does the proposed study have adequate sample size and power? Several studies have proposed improved ways to estimate sample size and power using existing meta-analyses. Involving a statistician to consider applying these methods may be appropriate. 27-29
3. Based on the findings from the SR and the body of evidence, which of the features that have been identified as being different to the proposed study should be modified, and which can it be justified to leave unchanged?
4. Which components of the proposed study are redundant with specific aspects of the PICOTS that are already answered (as opposed to the entire question already being answered)?
5. Does the proposed study do something completely new and relevant that has not been covered in either an SR or in other original studies (and, therefore, might not have been identified using the framework)?
6. Are research studies currently underway which will address these gaps? This should involve searches for ongoing trials using databases such as clinicaltrials.gov, VA Health Services Research & Development Web site, and the meta-register of controlled clinical trials (controlled-trials.com). A search for ongoing studies may not be a standard component of all SRs (although authors of reviews may include this information), and may not be part of all research protocols, therefore it may be valuable to include a search for such ongoing trials at this stage.
7. Other considerations: Although strength (or lack of strength) of evidence existing is the most important basis on which to base decisions to propose a new clinical trial, there may be other considerations. These include a balanced assessment of the level of risk of an intervention compared with potential benefit, adverse events from proposed intervention, feasibility of intervention, generalizability of intervention, and costs.35