# References

1 Institute of Medicine. Knowing what works in health care: a roadmap for the nation. Eden J, Wheatley B, McNeil B, et al., editors. Washington, DC. The National Academies Press. 2008.
2 Viechtbauer W. Learning from the past: refining the way we study treatments. J Clin Epidemiol. 2010;63(9):980-2. [pmid: 20573485].
3 Chalmers I, Glasziou P. Avoidable waste in the production and reporting of research evidence. Obstet Gynecol. 2009;114(6):1341-5. [pmid: 19935040].
4 Clarke M. Doing new research? Don't forget the old. PLos Med. 2004;1(2):100-2.
5 Goudie AC, Sutton AJ, Jones DR, et al. Empirical assessment suggests that existing evidence could be used more fully in designing randomized controlled trials. J Clin Epidemiol. 2010;63(9):983-91. [pmid: 20573483].
6 Cooper NJ, Jones DR, Sutton AJ. The use of systematic reviews when designing studies. Clin Trials. June. 1. 2005. 2005;2(3):260-4. [pmid: 16279149].
7 Clarke M, Hopewell S, Chalmers I. Reports of clinical trials should begin and end with up-to-date systematic reviews of other relevant evidence: a status report. JRSM. April. 1. 2007. 2007;100(4):187-90.
8 Howick J, Chalmers I, Glasziou P, et al. The 2011 Oxford CEBM levels of evidence: Introductory document. Oxford, UK. Oxford Centre for Evidence-Based Medicine. 2011.
9 McAlister FA, Laupacis A, Wells GA, et al. Users' guides to the medical literature. JAMA. October. 13. 1999. 1999;282(14):1371-7. [pmid: 10527185].
10 Shea BJ, Hamel C, Wells GA, et al. AMSTAR is a reliable and valid measurement tool to assess the methodological quality of systematic reviews. J Clin Epidemiol. 2009;62(10):1013-20. [pmid: 19230606].
11 Clarke L, Clarke M, Clarke T. How useful are Cochrane reviews in identifying research needs?. J Health Serv Res Po. April. 1. 2007. 2007;12(2):101-3.
12 Moher D, Cook DJ, Eastwood S, et al. Improving the quality of reports of meta-analyses of randomised controlled trials: the QUOROM statement. Lancet. 1999;354(9193):1896-900. [pmid: 10584742].
13 Moher D, Liberati A, Tetzlaff J, et al. Preferred reporting items for systematic reviews and meta-analyses: the PRISMA Statement. PLoS Med. 2009;6(7):1-6.
14 Savard L, Thompson D, Clark A. A meta-review of evidence on heart failure disease management programs: the challenges of describing and synthesizing evidence on complex interventions. Trials. 2011;12(1):194. [pmid: 21846340].
15 Ioannidis J, Patsopoulos N, Evangelou E. Uncertainty in heterogeneity estimates in meta-analysis. BMJ. 2007;335(7626):914-8. [pmid: 17974687].
16 Pauling L. How to Live Longer and Feel Better. New York. WH Freeman and Company. 1986.
17 Knipschild P. Systematic reviews: some examples. BMJ. 1994;309(6956):719-21. [pmid: 7950526].
18 Robinson K, Saldanha IJ, McKoy N. Frameworks for determining research gaps during systematic reviews. Methods Future Research Needs Report No. 2. AHRQ Publication No. 11-EHC043-EF. Rockville, MD. Agency for Healthcare Research and Quality. 2011.
19 Brasure M, Shamliyan T, Butler M, et al. Finding Evidence on Ongoing Studies. Methods Future Research Needs Report No. 1. AHRQ Publication No. 11-EHC018-EF. Rockville, MD. Agency for Healthcare Research and Quality. 2010.
20 O'Haire C, McPheeters M, Nakamoto E, et al. Methods for Engaging Stakeholders to Identify and Prioritize Future Research Needs. Methods Future Research Needs Report No. 4. AHRQ Publication No. 11-EHC044-EF. Rockville, MD. Agency for Healthcare Research and Quality. 2011.
21 Meltzer D, Hoomans T, Chung J, et al. Minimal Modeling Approaches to Value of Information Analysis for Health Research. Methods Future Research Needs Report No. 6. Rockville, MD. Agency for Healthcare Research and Quality. 2011.
22 Myers E, Sanders G, Ravi D, et al. Evaluating the Potential Use of Modeling and Value-of-Information Analysis for Future Research Prioritization Within the Evidence-based Practice Center Program. AHRQ Publication No. 11-EHC030-EF. Rockville, MD. Agency for Healthcare Research and Quality. 2011.
23 Trikalinos T, Dahabreh I, Lee J, et al. Methods Research on Future Research Needs: Defining an Optimal Format for Presenting Research Needs. Methods Future Research Needs Report No. 3. AHRQ Publication No. 11-EHC027-EF. Rockville, MD. Agency for Healthcare Research and Quality. 2011.
24 Viswanathan M, Nerz P, Dalberth B, et al. Assessing the Impact of AHRQ Evidence-based Practice Center (EPC) Reports on Future Research. Methods Future Research Needs Report No. 7. AHRQ Publication No. 11-EHC058-EF. Rockville, MD. Agency for Healthcare Research and Quality. 2011.
25 Atkins D, Chang SM, Gartlehner G, et al. Assessing applicability when comparing medical interventions: AHRQ and the Effective Health Care Program. J Clin Epidemiol. 2011;64(11):1198-207. [pmid: 21463926].
26 National Institute for Health Research. NIHR Health Technology Assessment programme: About the HTA programme. www.hta.ac.uk/about/index.shtml. September 15, 2011.
27 Sutton A, Cooper N, Jones D. Evidence synthesis as the key to more coherent and efficient research. BMC Med Res Meth. 2009;9(1):29.
28 Sutton AJ, Cooper NJ, Jones DR, et al. Evidence-based sample size calculations based upon updated meta-analysis. Statist Med. 2007;26(12):2479-500.
29 Borm GF, Bloem BR, Munneke M, et al. A simple method for calculating power based on a prior trial. J Clin Epidemiol. 2010;63(9):992-7. [pmid: 20573484].
30 Eckermann S, Karnon J, Willan A. The value of information: best informing research design and prioritization using current methods. PharmacoEconomics. 2010;28(9):699-709. [pmid: 20629473].
31 Basu A, Meltzer D. Modeling comparative effectiveness and the value of research. Ann Intern Med. August. 4. 2009. 2009;151(3):210-1. [pmid: 19652188].
32 Center for Evidence based Medicine. http://www.cebm.net/index.aspx?o=1157. September 15, 2011.
33 Perera R, Heneghan C. Interpreting meta-analysis in systematic reviews. EBM. June. 1. 2008. 2008;13(3):67-9.
34 Shojania KG, Sampson M, Ansari MT, et al. How quickly do systematic reviews go out of date? A survival analysis. Ann Intern Med. August. 21. 2007. 2007;147(4):224-33. [pmid: 17638714].
35 Kramer B, Wilentz J, Alexander D. Getting it right: being smarter about clinical trials. PLos Med. 2006;3(6):756-61.
36 Kessler R, Glasgow RE. A proposal to speed translation of healthcare research into practice: dramatic change is needed. Am J Prev Med. 2011;40(6):637-44. [pmid: 21565657].