# Key Informants

Carl Heneghan, B.M., B.Ch., M.A. (Hons), MRCGP

Director of the Centre for Evidence-Based Medicine

University of Oxford

Oxford, England

Dr. Rafael Perera, M.Sc., D.Phil.

Senior Fellow in Statistics

Department of Primary Health Care Sciences & Clinical Trials Unit

University of Oxford

Oxford, England

Ann van den Bruel M.D., Ph.D.

Clinical Lecturer

Department of Primary Health Care Sciences

University of Oxford

Oxford, England

Mark Helfand, M.D., M.S., M.P.H.

Director, Oregon Evidence-based Practice Center

Professor, Department of Medical Informatics and Clinical Epidemiology

Oregon Health & Science University

Staff Physician, Portland Veterans Affairs Medical Center

Portland, Oregon