# Methods

## Design of Framework

We used a multiphase process to identify existing and relevant materials related to the identification of research gaps, adapted some of them in the development of the framework and attempted to apply it to existing systematic reviews (SRs). In a final step we sought external feedback from several experts in this field.

### Phase 1

We used a focused literature search to identify and critique existing frameworks and processes that have been proposed as methods to identify research gaps in SRs. Within this search we examined all Future Research Needs (FRN) methods working papers for work relevant to our aim.18,19-24 We also searched for relevant checklists and tools with the explicit aim of incorporating these where appropriate. For example we incorporated checklists and tools published by the FRN methods project related to identifying research gaps,18 tools that have been designed for rapid appraisal of SRs,8 principles identified regarding the applicability of SRs for clinical populations,25 and methods used by a non-United States research funding agency26 to critically assess proposed trials of interventions.

### Phase 2

We then convened a multidisciplinary group with expertise in evidence synthesis, primary research, biostatistics, and clinical epidemiology. Over a series of meetings, this group used an iterative process to develop a stepwise framework. We explicitly attempted to include existing published materials to inform sections of the framework.

### Phase 3

We then attempted to apply the framework to specifically proposed clinical research questions. We identified two current SRs and came up with corresponding pseudo research questions. We then applied the draft versions of the framework to the combination of the research question and the contemporaneous SR and applied these to draft versions of the framework. See Appendixes A and B.

### Phase 4

In a final phase, we invited external opinions from four additional experts with experience in clinical epidemiology, health technology assessment, medical statistics, clinical trials, and Cochrane reviews in order to further modify the content and structure of the proposed framework.

Based on the four-phase process, a final version of the framework was produced.