# Introduction

## Background

### The Role of Systematic Reviews in Guiding Future Research

It is well established that systematic reviews (SRs) may provide comprehensive summaries of existing evidence using structured and robust methods. Consequently, SRs have achieved a central place in informing decision making from the level of individual patient care to health care policymakers.1 By identifying and summarizing the existing state of evidence within a given clinical area, SRs also serve to identify existing gaps in a body of evidence. Such gaps have a number of important implications, particularly in highlighting the limitations in the conclusions that can be drawn from the SRs for patients, clinicians, and policymakers.

SRs and meta-analyses are also a potentially valuable resource for clinical researchers in the process of designing or proposing new research studies. Arguably, for maximum efficiency, new primary research studies should specifically answer those gaps identified in an existing body of evidence which are of greatest priority to clinicians, patients, and health care policymakers. By addressing established and important research gaps, new research studies would be expected to provide the greatest impact on health care. However, while optimal, we suggest that this is currently not standard practice for many clinical researchers proposing new research studies. One reason may be that the approaches and methods of systematic reviewers and primary researchers are fundamentally different. The focus of the former is identifying and summarizing “what has been found,” whereas the latter may have much more diverse reasons to design or propose new research studies: clinical experience, perceived or real gaps in clinical practice, or in response to new interventions.2

This working paper therefore describes the development of a proposed new framework that is intended to be used by researchers when designing new clinical research studies. The framework is intended to provide structured guidance to allow clinical researchers to compare the essential elements of possible new studies with the findings of prior related SRs. It provides a structured approach to considering possible implications of information typically reported in well-done published SRs for the design of new study proposals. The overall aim is to help reduce proposals that are redundant on the basis of existing research; help refine the focus of proposals on the most relevant populations, interventions, comparators, outcomes and settings; and help to assure that research addresses clearly established and important gaps in the existing evidence.

The target users of the framework are clinical researchers involved in the early design or protocol writing phases of new trials of interventions. This is a different focus from previous attempts to determine research gaps from SRs, which have been primarily aimed at those who conduct or routinely use systematic/comparative effectiveness reviews. Indeed, the proposed framework is intended to be applied by those who have limited experience in critically appraising SRs or meta-analyses, but who have a high level of content expertise in their particular area of research.

### Suboptimal Use of Research Funding: “Research Wastage”

The concept that a proportion of the current biomedical research budget (approximately $100 billion in the United States alone) may not be used optimally (i.e., is “wasted”), has been raised by Chalmers and Glasziou.3 The authors suggest at least four areas in the production and reporting of research in which this might occur. First, research questions posed may lack relevance to clinicians and patients. Second, studies may be conducted that do not consider the prior existing evidence as summarized and assessed in previously conducted SRs or may be poorly designed. Third, results of studies may not be accessible or published. Fourth, published reports may be biased and not useable, for example by failing to describe interventions adequately or all study outcomes, and may not interpret them in the context of existing SRs. Across these main categories the authors note the central role of SRs: informing the need for, or designing of new research studies, and interpreting the findings of new research studies in the light of existing SRs.

Research wastage has financial and ethical implications.4 From the perspective of funders of research, it implies that at least a proportion of biomedical research budgets may be used inefficiently (or even inappropriately), diverting resources from other research priorities or other budgets. From patient perspectives, it implies that patients may be subject to research studies which may not be necessary, may be harmful because previous studies have already shown they are not beneficial, or use interventions which have not been adequately studied due to the fact that research resources have been utilized elsewhere. From an overall societal perspective, it implies that a proportion of efforts and resources may not be applied as effectively as possible for the maximum benefit.

### Frequency of Use of Systematic Reviews in Research Design

SRs are used infrequently in the design of new research studies. Goudie, et al. assessed a sample of randomized controlled trials (RCTs) published in leading medical journals in 2007 to determine whether or not “authors had considered previous trials in design of their trial.”5 Only 6 of the 27 RCTs examined (22 percent) reported that they had used the findings of previous RCTs in sample size calculations, and only 10 of the 27 RCTs (37 percent) related the results of the new trial in the light of meta-analyses in the trial discussion sections. Cooper, et al. contacted authors of all trials added to the 2002 or 2003 updates of Cochrane SRs originally published in 1996, to determine how frequently the results of the 1996 Cochrane reviews had been used in the design of the subsequent studies.6 They received responses from 24 authors of the 32 studies which were newly included in the 2002/2003 Cochrane reviews (75 percent response rate). Less than half (11; 46 percent) of respondents were aware of the relevant Cochrane review when they had designed their new study, and in only a third (8; 33 percent) was the design of the new study influenced by the review.6

Clarke, et al. assessed reports of 18 RCTs published in the five leading medical journals in 2005.^7^ Only 5 (27 percent) of published trials referred to existing SRs in their introduction sections. Moreover, the authors noted that “none of the 15 trials which were not the first published trials in their area placed the results of the new trial in the context of an updated SR or other research.” In addition, when the same authors compared these results to a previous assessment of the 55 reports of RCTs carried out in 1997 and 2001, only 2 placed the new results in the context of SRs, and only 7 referred to SRs in the discussion sections of the published trials.7 This suggests there has been no improvement in the use of SRs in design of RCTs over the decade.

### Potential Reasons Why Systematic Reviews May Not Be Used When Designing New Studies

There are several reasons why the results of SRs may not currently be used by researchers to inform the design of proposed new research studies:

#### Systematic Review May Not Exist

Despite the growing pool of SRs, they still only address a limited proportion of all trials of interventions. In part this reflects the challenges in not only conducting, but also updating SRs. However, for other types of study, such as diagnostic test accuracy studies, the methodology for conducting SRs is less established, and a far smaller proportion of such studies are likely to have been included in SRs.

#### Unaware of Existence of Systematic Reviews

The researcher may be unaware of the existence of relevant SRs in the particular research area in which they are interested. Currently the majority of SRs of interventions can be identified readily using several different searching tools, but this requires at least some degree of proficiency in searching and retrieval of relevant reviews.

#### Inadequate Critical Appraisal Skills

Researchers may vary in their ability to critically appraise the relevance and internal validity of SRs. This is important because the results of reviews which have been conducted systematically using accepted standards may differ from those which have not and which may present partial or biased summaries of the literature. There are multiple tools that have been designed to facilitate the appraisal of SRs. These include checklists designed predominantly for clinical users8, 9 as well as more complex checklists and quality rating systems.10 However, researchers may be unaware of these instruments or may lack the skills to use them.

#### Systematic Reviews Do Not Use a Defined or Transparent Process for Reporting the Evidence Gaps

The majority (if not all) of SRs highlight research gaps in the body of evidence included in the SR, although the process used by the review authors to identify (or prioritize) them may be opaque and potentially open to bias.

A survey of all 2,535 reviews published in the Cochrane Library in 2007 found that only 3.2 percent stated explicitly that no more research was needed, whereas 82.0 percent of reviews made suggestions regarding the interventions that needed evaluating, 30.2 percent suggested the appropriate participants that needed studying, and 51.9 percent suggested the outcome measures.11 However, it is unclear the extent to which this occurs in other (non-Cochrane) SRs.

Evidence gaps are seldom reported explicitly, but rather they may be reported under the heading “implications for research” or more generally in the sentence “more research is needed,” following the guidelines of the QUORUM statement on the quality of reporting of meta-analyses.12 These guidelines have now been updated to PRISMA13 which also includes an item for reporting in the conclusion, “a general interpretation of the results in the context of other evidence, and implications for future research.”

Often, authors focus on what is available and do not explicitly report what is not available.2 A failure to identify evidence gaps may be caused by inadequate reporting overall. A meta-review including 15 SRs on heart failure disease management programs found that populations, intervention components, comparator groups, and other important characteristics were inadequately reported.14 A review of 192 trials from seven different medical areas found that safety reporting was inadequate in the entire sample.15

#### Deliberately Ignoring Systematic Reviews

The deliberate selection of evidence has been described as cherry picking: selecting only the juiciest and ripest fruit. In science this may be done to support a researcher's view and justify a new research proposal. A famous example is that of Linus Pauling describing the effects of vitamin C on the common cold.16 In his book How to Live Longer and Feel Better, he cites more than 30 studies, nearly all with positive results, when in fact there were 61 trials showing vitamin C cannot prevent colds and has only minimal effects on duration and severity.17 The extent to which this occurs in current research proposals is not known.

## Aim of Study

We therefore aimed to develop a pragmatic framework to help researchers use findings from SRs in designing and conducting new clinical research studies. This framework is intended to provide a structured process for researchers to identify SRs which are relevant to their proposed new study, identify gaps, and use study design features from studies included in the SR to inform the design of a new research study.