# Discussion

The proposed framework attempts to provide a practical method to improve the use of systematic review (SR) findings in the design and conduct of new research studies. The framework has been designed to be used by researchers rather than systematic reviewers, and thus provides a contrast to the perspective of many other initiatives in this area. It is not intended to be applied as a simple checklist or “tick-box exercise,” rather it requires the in depth knowledge about a particular clinical research area which only a primary research is likely to have, and requires a degree of judgment in several steps. The four-step process is intended for researchers who are in the design phase of study proposal or protocol writing, and involves: Step 1, clearly laying out the crucial design elements of the proposed study using PICOTS elements; Step 2, identifying an existing SR which is current, valid, and relevant enough to the proposed research study; Step 3, examining the details of the SR to determine the extent to which it has already addressed the questions proposed by the new study and identifying the PICOTS elements of the primary studies included in the SR which can be used to modify the design of the proposed study; and Step 4, establishing the need (or otherwise) for the proposed study and prioritizing modifications to research design.

In 2004, the Editor of the Cochrane Library, Dr. Mike Clarke, suggested that researchers should “Design your study to take account of the relevant successes and failures of the prior studies, and of the evidence within them.”4 As we highlighted in the introduction, currently only a minority of trials of interventions appear to incorporate the results of existing SRs in their design. We suggest that this contributes to research “wastage” or the inefficient process of conducting new research studies with insufficient attention to existing literature. Indeed, some commentators have proposed a moratorium on new efficacy randomized controlled trials to give researchers and others necessary time to “collaboratively identify and evaluation innovations that have real potential for translation.”36 There are numerous reasons why SRs may not currently be used by researchers to inform study design. The proposed framework attempts to address some of these potential reasons—namely that researchers may lack critical appraisal skills in order to be able to evaluate published SRs effectively, and that SRs in their current format present findings in a way that does not make it straightforward for primary researchers to use inform their future research study.

Most of the current literature on improving the use of SRs in research study design has arisen from the perspective of statistics, and there have been several proposals for improving the use of meta-analyses in simulating sample size and power calculations. These are important, yet focus on particular findings from the meta-analysis and ignore other aspects of study design and indeed need for further studies. As Viechtbauer noted in 2010, “focus on sample size considerations should not draw our attention away from other design issues that can and should be informed by previous research.”2 The Future Research Needs (FRN) methods project, “Frameworks for Determining Research Gaps During Systematic Reviews” provides a useful way of categories gaps identified in the PICOTS elements using four categories of insufficient or imprecise information, biased information, inconsistency or unknown consistency, and not the right information,18 and we have incorporated this categorization in Step 3 of the current framework. In contrast to the proposed study, the FRN project focus was primarily that of systematic reviewers, rather than clinical researchers in the process of proposing or writing the protocols for new research studies. We therefore aimed to add to this FRN project by providing a more pragmatic “tool” that clinical researchers could use to operationalize some of the principles and initial guidance provided in the FRN project.

A possible limitation of the proposed framework is the danger in prioritizing the need for further research based solely on evidence of effect (or evidence of lack of effect). Publication bias suggests that there is a tendency to publish only when findings are significant, and only when showing positive effect. Even when there is confidence in the size and direction of an effect, it is still possible that additional trials could alter the direction of effect, and there are examples of where evidence of effective treatment based on a meta-analysis have been changed by subsequent trials. Another reason to propose further small trials is that they may demonstrate greater generalizability, which may not be possible from a single larger trial. However, this caution would apply to all frameworks, and we have attempted to use a broader perspective than merely examining the results of a SR meta-analysis in order to judge the need (or not) for a further study. A further limitation of the proposed framework is that we do not know whether most clinical researchers currently have the skill in order to use SRs in the manner in which we have proposed. In addition, we do not know if the proposed framework offers advantages over other attempts to improve the usefulness of SRs for indicating future research gaps, such as better reporting or more explicit mention of research gaps.11

The following next steps could be considered in methodology research in this area. First, although the proposed framework has been designed from the perspective of the primary researcher and has received feedback from several individuals involved in trial design, we do not know how useful this framework is for primary researchers. Therefore using a wider group of stakeholders to evaluate the proposed framework, in particular engaging with researchers in the proposal phase of new research studies in order to use the framework “for real,” would be valuable. Second, one possible way of “testing” the framework would be to identify a series of trials published in a set of the main medical journals in 2011, identify the original protocols of the trials (e.g., from clinical trials.gov), and determine whether application of the framework at the time of the protocol publication would have been useful to modify the protocol, and in what ways. Third, it would be useful to consider whether the current framework could benefit from making more explicit for primary researchers the situations in which the data from meta-analyses could be used more effectively. This could include alternative methods of meta-analyses, such as individual patient data meta-analysis. Currently primary researchers would have little way of knowing the “triggers” for when to consider an individual patient data meta-analysis rather than a further primary research study.