# Appendixes

Appendix A Assessing Validity of Systematic Reviews

Appendix B Four-Step Framework Example 1: Corticosteroids for Pain Relief in Sore Throat: Systematic Review and Meta-analysis