# Four-Step Framework Example 1: Corticosteroids for Pain Relief in Sore Throat: Systematic Review and Meta-analysis

Hayward G, Thompson M, Heneghan C, et al. Corticosteroids for pain relief in sore throat: systematic review and meta-analysis. BMJ. 2009;339:b2976. [pmid: 19661138].

Step | Substeps | Proposed New Study | Systematic Review
Step 1: Outline the PICO of the proposed new study. | Intervention | Corticosteroids | NA
Step 1: Outline the PICO of the proposed new study. | Patient group | Adults | NA
Step 1: Outline the PICO of the proposed new study. | Setting | Outpatient | NA
Step 1: Outline the PICO of the proposed new study. | Control or comparator | Tylenol | NA
Step 1: Outline the PICO of the proposed new study. | Study design | RCT | NA
Step 1: Outline the PICO of the proposed new study. | Main/important outcomes | Improvement in pain | NA
Step 1: Outline the PICO of the proposed new study. | Duration of followup | 1 week | NA
Step 2: Identify a relevant, valid and current systematic review. Is it relevant? | Intervention | Oral corticosteroids | Systemic corticosteroid
Step 2: Identify a relevant, valid and current systematic review. Is it relevant? | Patient group | Adults | Adults and children
Step 2: Identify a relevant, valid and current systematic review. Is it relevant? | Setting | Outpatient | Outpatient (ambulatory)
Step 2: Identify a relevant, valid and current systematic review. Is it relevant? | Control or comparator | Tylenol or NSAIDs | Placebo
Step 2: Identify a relevant, valid and current systematic review. Is it relevant? | Study design | Observational | Randomized controlled trials
Step 2: Identify a relevant, valid and current systematic review. Is it relevant? | Main/important outcomes | Improvement in pain | Symptoms of sore throat
Step 2: Identify a relevant, valid and current systematic review. Is it relevant? | Duration of followup | 1 week | Not specified
Step 2: Identify a relevant, valid and current systematic review. Is it valid? | What question (PICO) did the systematic review address? | NA | Evaluated whether systemic corticosteroids improve symptoms of sore throat in adults and children.
Step 2: Identify a relevant, valid and current systematic review. Is it valid? | Comprehensive Literature Search? | NA | Yes: All major search engines were searched
Step 2: Identify a relevant, valid and current systematic review. Is it valid? | Criteria used to select articles for inclusion appropriate? | NA | Yes
Step 2: Identify a relevant, valid and current systematic review. Is it valid? | Included studies sufficiently valid for the type of questions asked? | NA | Unclear (8 studies included with 743 patients)
Step 2: Identify a relevant, valid and current systematic review. Is it valid? | Were the results similar from study to study? | NA | No. Heterogeneity exists in setting, intervention, outcomes, and severity of illness.
Step 2: Identify a relevant, valid and current systematic review. Is it current? | Is it Current? | NA | Yes: 2009
Step 3: Use the body of evidence from SR to inform the proposed research study. What can be learned from the primary studies included in the SR? | Intervention (type and number) | NA | Six studies used Dexamethasone (IM), one used Betamethasone (IM), and one used Prednisone (PO).
Step 3: Use the body of evidence from SR to inform the proposed research study. What can be learned from the primary studies included in the SR? | Intervention (type and number) | NA | Implications: very little data on use of oral steroids, which is most likely to be the type of steroids used in ambulatory settings.
Step 3: Use the body of evidence from SR to inform the proposed research study. What can be learned from the primary studies included in the SR? | Patient group | NA | Five studies used adults (age ranges from 12 to 65) and three used children (age ranges 5 to 16).
Step 3: Use the body of evidence from SR to inform the proposed research study. What can be learned from the primary studies included in the SR? | Patient group | NA | Implications: the effect was significant in adults but not children, but 4/5 adult studies used IM steroids not oral, the only one that did was based in Israel in patients with severe sore throat.
Step 3: Use the body of evidence from SR to inform the proposed research study. What can be learned from the primary studies included in the SR? | Setting | | Outpatient, variety of methods used to determine severity.
Step 3: Use the body of evidence from SR to inform the proposed research study. What can be learned from the primary studies included in the SR? | Setting | | Implications: need standardized way of assessing severity of sore throat and standardize throat swabbing.
Step 3: Use the body of evidence from SR to inform the proposed research study. What can be learned from the primary studies included in the SR? | Control or comparator | NA | Placebo in studies was IM saline or PO placebo, but all participants were given antibiotics.
Step 3: Use the body of evidence from SR to inform the proposed research study. What can be learned from the primary studies included in the SR? | Control or comparator | NA | Implication: need for study where participants are not given antibiotics, otherwise do not know the independent effects of steroids without abx.
Step 3: Use the body of evidence from SR to inform the proposed research study. What can be learned from the primary studies included in the SR? | Study design | NA | Randomized controlled trials.
Step 3: Use the body of evidence from SR to inform the proposed research study. What can be learned from the primary studies included in the SR? | Study design | NA | Implication: no justification for using inferior study design to this. None of the studies used pragmatic RCT, could consider this type of design.
Step 3: Use the body of evidence from SR to inform the proposed research study. What can be learned from the primary studies included in the SR? | Main/important outcomes | NA | Included studies used many different outcome measures related to pain, associated symptoms, and impact on quality of life.
Step 3: Use the body of evidence from SR to inform the proposed research study. What can be learned from the primary studies included in the SR? | Main/important outcomes | NA | Implication: select the validated visual analogue score used in several of the studies to measure pain. None of the studies examined recurrence within 1-2 weeks, or the effect on reattendance—consider adding these as secondary outcomes. None of the studies examined cost effectiveness, could add this to proposed study.
Step 3: Use the body of evidence from SR to inform the proposed research study. What can be learned from the primary studies included in the SR? | Duration of followup | NA | 72 hours followup in most studies.
Step 3: Use the body of evidence from SR to inform the proposed research study. What can be learned from the primary studies included in the SR? | Duration of followup | NA | Implication: 72 hours was sufficient as most participants completely improved by then, no need for longer followup for efficacy, might consider whether longer followup might be useful to look for impact on recurrence (of same episode) or re attendance (with new episodes).
Step 3: Use the body of evidence from SR to inform the proposed research study. What does the SR answer, and where do gaps remain? | Proposed study questions have already been answered adequately? | No | Corticosteroids provide symptomatic relief of pain in sore throat, in addition to antibiotic therapy, mainly in participants with severe or exudative sore throat.
Step 3: Use the body of evidence from SR to inform the proposed research study. What does the SR answer, and where do gaps remain? | Proposed study questions have already been answered adequately? | No | Evidence for effect on adults was significant, not for oral steroids, not for less severe sore throat.
Step 3: Use the body of evidence from SR to inform the proposed research study. What does the SR answer, and where do gaps remain? | Proposed study questions have not been answered adequately? | Yes | A. Insufficient data?
Step 3: Use the body of evidence from SR to inform the proposed research study. What does the SR answer, and where do gaps remain? | Proposed study questions have not been answered adequately? | Yes | Only 8 studies with a combined sample of 369 children and 374 adults, only 1 study of oral steroids, most participants had severe sore throat.
Step 3: Use the body of evidence from SR to inform the proposed research study. What does the SR answer, and where do gaps remain? | Proposed study questions have not been answered adequately? | Yes | B. Imprecise data?
Step 3: Use the body of evidence from SR to inform the proposed research study. What does the SR answer, and where do gaps remain? | Proposed study questions have not been answered adequately? | Yes | Limitations like antibiotic use, heterogeneity in outcome measures, imprecision for oral steroids and nonsevere sore throat
Step 3: Use the body of evidence from SR to inform the proposed research study. What does the SR answer, and where do gaps remain? | Proposed study questions have not been answered adequately? | Yes | C. Potentially biased information? Generic drugs, but possible reporting bias as all studies positive effect, authors stated that not possible to exclude publication bias.
Step 3: Use the body of evidence from SR to inform the proposed research study. What does the SR answer, and where do gaps remain? | Proposed study questions have not been answered adequately? | Yes | D. Inconsistency or unknown consistency?
Step 3: Use the body of evidence from SR to inform the proposed research study. What does the SR answer, and where do gaps remain? | Does it address gaps? | NA | Study in adults, with range of severity of sore throat, using oral steroids is justified.
Step 4: Summarizing the implications for proposed study. | Which components of proposed study are redundant? | NA | None
Step 4: Summarizing the implications for proposed study. | Balance of risk/benefit? | NA | Need to assess cost effectiveness. Effect size from SR is small (6 hours improvement with steroids) thus cost effectiveness may be major issue to generalizability of results.
Step 4: Summarizing the implications for proposed study. | Which features should be modified? | NA | Select valid pain score outcome measure, consider adding recurrence or re attendance as 2 year outcomes, type and dose of steroid, and severity of sore throat in included participants.