# Assessing Validity of Systematic Reviews

Comprehensive Literature Search

What is Best? | Where is This Information?
The starting point for a comprehensive search for all relevant studies is the major bibliographic databases (e.g., Medline, Cochrane, EMBASE, etc) but should also include a search of reference lists from relevant studies, and contact with experts, particularly to inquire about unpublished studies. The search should not be limited to English language only. The search strategy should include both MESH terms and text words. | The Methods section should describe the search strategy, including the terms used, in some detail. The Results section will outline the number of titles and abstracts reviewed, the number of full-text studies retrieved, and the number of studies excluded together with the reasons for exclusion. This information may be presented in a figure or flow chart.
Comment:

Criteria Used to Select Articles for Inclusion Appropriate?

What is Best? | Where is This Information?
The inclusion or exclusion of studies in a systematic review should be clearly defined a priori. The eligibility criteria used should specify the patients, interventions or exposures and outcomes of interest. In many cases the type of study design will also be a key component of the eligibility criteria. | The Methods section should describe in detail the inclusion and exclusion criteria. Normally, this will include the study design.
Comment:

Included Studies Sufficiently Valid for the Type of Question Asked?

What is Best? | Where is This Information?
The article should describe how the quality of each study was assessed using predetermined quality criteria appropriate to the type of clinical question and the study design (e.g., randomization, blinding, and completeness of follow-up) | The Methods section should describe the assessment of quality and the criteria used. The Results section should provide information on the quality of the individual studies.
Comment:

Were the Results Similar From Study to Study?

What is Best? | Where is This Information?
Ideally, the results of the different studies should be similar or homogeneous. If heterogeneity exists the authors may estimate whether the differences are significant (chi-square test). Possible reasons for the heterogeneity should be explored. | The Results section should state whether the results are heterogeneous and discuss possible reasons. The forest plot should show the results of the chi-square test for heterogeneity and if discuss reasons for heterogeneity, if present.
Comment: