# Acronyms and Abbreviations

AHRQ: Agency for Healthcare Research and Quality
EPC: Evidence-based Practice Center
FRN: Future Research Needs
RCT: Randomized controlled trial
SR: Systematic review
VOI: Value of information