# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Mark Helfand, M.D., M.S., M.P.H., Jeanne-Marie Guise, M.D., M.P.H., and Elaine Graham, M.L.S.