# References

1 Lord SJ, Irwig L, Simes RJ. When is measuring sensitivity and specificity sufficient to evaluate a diagnostic test, and when do we need randomized trials?. Ann Intern Med. Jun. 6. 2006;144(11):850-5. [pmid: 16754927].
2 Trikalinos TA, Siebert U, Lau J. Decision-analytic modeling to evaluate benefits and harms of medical tests: uses and limitations. Med Decis Making. Sep–Oct. 2009;29(5):E22-9. Epub 2009 Sep 4. [pmid: 19734441].
3 Irwig L, Tosteson AN, Gatsonis C, et al. Guidelines for meta-analyses evaluating diagnostic tests. Ann Intern Med. Apr. 15. 1994;120(8):667-76. [pmid: 8135452].
4 Lau J, Ioannidis JP, Schmid CH. Summing up evidence: one answer is not always enough. Lancet. Jan. 10. 1998;351(9096):123-7. [pmid: 9439507].
5 Lijmer JG, Leeflang M, Bossuyt PM. Proposals for a phased evaluation of medical tests. Med Decis Making. Sep–Oct. 2009;29(5):E13-21. [pmid: 19605881].
6 Lord SJ, Irwig L, Bossuyt PM. Using the principles of randomized controlled trial design to guide test evaluation. Med Decis Making. Sep–Oct. 2009;29(5):E1-E12. [pmid: 19773580].
7 Tatsioni A, Zarin DA, Aronson N, et al. Challenges in systematic reviews of diagnostic technologies. Ann Intern Med. Jun. 21. 2005;142(12 Pt 2):1048-55. [pmid: 15968029].
8 Reitsma JB, Glas AS, Rutjes AW, et al. Bivariate analysis of sensitivity and specificity produces informative summary measures in diagnostic reviews. J Clin Epidemiol. 2005;58(10):982-90. [pmid: 16168343].
9 Rutter CM, Gatsonis CA. Regression methods for meta-analysis of diagnostic test data. Acad Radiol. 1995;2(Suppl 1):S48-S56. [pmid: 9419705].
10 Kliegman RM, Behrman RE, Jenson HB, et al. Nelson textboook of pediatrics. Philadelphia, PA. Saunders. 2007.
11 Smith-Bindman R, Hosmer W, Feldstein VA, et al. Second-trimester ultrasound to detect fetuses with Down syndrome: a meta-analysis. JAMA. Feb. 28. 2001;285(8):1044-55. [pmid: 11209176].
12 Palomaki GE, Deciu C, Kloza EM, et al. DNA sequencing of maternal plasma reliably identifies trisomy 18 and trisomy 13 as well as Down syndrome: an international collaborative study. Genet Med. Mar. 2012;14(3):296-305. [pmid: 22281937].
13 Benacerraf BR, Neuberg D, Frigoletto FD Jr. Humeral shortening in second-trimester fetuses with Down syndrome. Obstet Gynecol. Feb. 1991;77(2):223-7. [pmid: 1824870].
14 Benacerraf BR, Neuberg D, Bromley B, et al. Sonographic scoring index for prenatal detection of chromosomal abnormalities. J Ultrasound Med. Sep. 1992;11(9):449-58. [pmid: 1283415].
15 Benacerraf BR, Nadel A, Bromley B. Identification of second-trimester fetuses with autosomal trisomy by use of a sonographic scoring index. Radiology. Oct. 1994;193(1):135-40. [pmid: 8090881].
16 Biagiotti R, Periti E, Cariati E. Humerus and femur length in fetuses with Down syndrome. Prenat Diagn. Jun. 1994;14(6):429-34. [pmid: 7937578].
17 Bromley B, Lieberman E, Benacerraf BR. The incorporation of maternal age into the sonographic scoring index for the detection at 14–20 weeks of fetuses with Down’s syndrome. Ultrasound Obstet Gynecol. Nov. 1997;10(5):321-4. [pmid: 9444045].
18 Johnson MP, Michaelson JE, Barr M Jr, et al. Combining humerus and femur length for improved ultrasonographic identification of pregnancies at increased risk for trisomy 21. Am J Obstet Gynecol. Apr. 1995;172(4 Pt 1):1229-35. [pmid: 7726261].
19 Lockwood CJ, Lynch L, Ghidini A, et al. The effect of fetal gender on the prediction of Down syndrome by means of maternal serum alpha-fetoprotein and ultrasonographic parameters. Am J Obstet Gynecol. Nov. 1993;169(5):1190-7. [pmid: 7694466].
20 Nyberg DA, Resta RG, Luthy DA, et al. Humerus and femur length shortening in the detection of Down’s syndrome. Am J Obstet Gynecol. Feb. 1993;168(2):534-8. [pmid: 8438923].
21 Nyberg DA, Luthy DA, Resta RG, et al. Age-adjusted ultrasound risk assessment for fetal Down’s syndrome during the second trimester: description of the method and analysis of 142 cases. Ultrasound Obstet Gynecol. Jul. 1998;12(1):8-14. [pmid: 9697277].
22 Rodis JF, Vintzileos AM, Fleming AD, et al. Comparison of humerus length with femur length in fetuses with Down syndrome. Am J Obstet Gynecol. Oct. 1991;165(4 Pt 1):1051-6. [pmid: 1835298].
23 Vintzileos AM, Egan JF, Smulian JC, et al. Adjusting the risk for trisomy 21 by a simple ultrasound method using fetal long-bone biometry. Obstet Gynecol. Jun. 1996;87(6):953-8. [pmid: 8649705].
24 Campbell WA, Vintzileos AM, Rodis JF, et al. Efficacy of the biparietal diameter/femur length ratio to detect Down syndrome in patients with an abnormal biochemical screen. Fetal Diagn Ther. May–Jun. 1994;9(3):175-82. [pmid: 7520246].
25 Ginsberg N, Cadkin A, Pergament E, et al. Ultrasonographic detection of the second-trimester fetus with trisomy 18 and trisomy 21. Am J Obstet Gynecol. Oct. 1990;163(4 Pt 1):1186-90. [pmid: 2145768].
26 Cuckle H, Wald N, Quinn J, et al. Ultrasound fetal femur length measurement in the screening for Down’s syndrome. BJOG. Dec. 1989;96(12):1373-8.
27 Dicke JM, Gray DL, Songster GS, et al. Fetal biometry as a screening tool for the detection of chromosomally abnormal pregnancies. Obstet Gynecol. Nov. 1989;74(5):726-9. [pmid: 2530480].
28 Benacerraf BR, Cnann A, Gelman R, et al. Can sonographers reliably identify anatomic features associated with Down syndrome in fetuses? Radiology. Nov. 1989;173(2):377-80.
29 Brumfield CG, Hauth JC, Cloud GA, et al. Sonographic measurements and ratios in fetuses with Down syndrome. Obstet Gynecol. Apr. 1989;73(4):644-6. [pmid: 2522612].
30 Grandjean H, Sarramon MF. Femur/foot length ratio for detection of Down syndrome: results of a multicenter prospective study. The Association Francaise pour le Depistage et la Prevention des Handicaps de l’Enfant Study Group. Am J Obstet Gynecol. Jul. 1995;173(1):16-9. [pmid: 7631674].
31 Johnson MP, Barr M Jr, Treadwell MC, et al. Fetal leg and femur/foot length ratio: a marker for trisomy 21. Am J Obstet Gynecol. Sep. 1993;169(3):557-63. [pmid: 8372862].
32 Grist TM, Fuller RW, Albiez KL, et al. Femur length in the US prediction of trisomy 21 and other chromosomal abnormalities. Radiology. Mar. 1990;174(3 Pt 1):837-9. [pmid: 2137635].
33 LaFollette L, Filly RA, Anderson R, et al. Fetal femur length to detect trisomy 21. A reappraisal. J Ultrasound Med. Dec. 1989;8(12):657-60. [pmid: 2531234].
34 Hill LM, Guzick D, Belfar HL, et al. The current role of sonography in the detection of Down syndrome. Obstet Gynecol. Oct. 1989;74(4):620-3. [pmid: 2529461].
35 Lockwood C, Benacerraf B, Krinsky A, et al. A sonographic screening method for Down syndrome. Am J Obstet Gynecol. Oct. 1987;157(4 Pt 1):803-8. [pmid: 2960238].
36 Verdin SM, Economides DL. The role of ultrasonographic markers for trisomy 21 in women with positive serum biochemistry. BJOG. Jan. 1998;105(1):63-7.
37 Nyberg DA, Luthy DA, Cheng EY, et al. Role of prenatal ultrasonography in women with positive screen for Down syndrome on the basis of maternal serum markers. Am J Obstet Gynecol. Oct. 1995;173(4):1030-5. [pmid: 7485289].
38 Marquette GP, Boucher M, Desrochers M, et al. Screening for trisomy 21 with ultrasonographic determination of biparietal diameter/femur length ratio. Am J Obstet Gynecol. Nov. 1990;163(5 Pt 1):1604-5. [pmid: 2146880].
39 Nyberg DA, Resta RG, Hickok DE, et al. Femur length shortening in the detection of Down syndrome: is prenatal screening feasible? Am J Obstet Gynecol. May. 1990;162(5):1247-52.
40 Shah YG, Eckl CJ, Stinson SK, et al. Biparietal diameter/femur length ratio, cephalic index, and femur length measurements: not reliable screening techniques for Down syndrome. Obstet Gynecol. Feb. 1990;75(2):186-8. [pmid: 2137210].
41 Lynch L, Berkowitz GS, Chitkara U, et al. Ultrasound detection of Down syndrome: is it really possible? Obstet Gynecol. Feb. 1989;73(2):267-70.
42 Chu H, Cole SR. Bivariate meta-analysis of sensitivity and specificity with sparse data: a generalized linear mixed model approach. J Clin Epidemiol. Dec. 2006;59(12):1331-1332. author reply 1332–3. [pmid: 17098577].
43 Macaskill P. Empirical Bayes estimates generated in a hierarchical summary ROC analysis agreed closely with those of a full Bayesian analysis. J Clin Epidemiol. Sep. 2004;57(9):925-32. [pmid: 15504635].
44 Trikalinos TA, Balion CM, Coleman CI, et al. Chapter 8: Meta-analysis of Test Performance When There Is A “Gold Standard”. J Gen Intern Med. Jun. 2012;27(Suppl 1):S56-66. [pmid: 22648676].
45 Stijnen T, Hamza TH, Ozdemir P. Random effects meta-analysis of event outcome in the framework of the generalized linear mixed model with applications in sparse data. Stat Med. Dec. 20. 2010;29(29):3046-67. [pmid: 20827667].
46 Hamza TH, van Houwelingen HC, Stijnen T. The binomial distribution of meta-analysis was preferred to model within-study variability. J Clin Epidemiol. Jan. 2008;61(1):41-51. [pmid: 18083461].
47 Miller R. Simultaneous statistical inference. 2nd ed. New York. Springer Verlag. 1981.
48 Lu G, Ades A. Modeling between-trial variance structure in mixed treatment comparisons. Biostatistics. Oct. 2009;10(4):792-805. [pmid: 19687150].
49 Pinheiro JC, Bates DM. Unconstrained parametrizations for variance-covariance matrices. Stat Comput. Sep. 1996;6(3):289-96.
50 Riley RD, Abrams KR, Lambert PC, et al. An evaluation of bivariate random-effects meta-analysis for the joint synthesis of two correlated outcomes. Stat Med. Jan. 15. 2007;26(1):78-97. [pmid: 16526010].
51 Trikalinos TA, Trow P, Schmid CH. Simulation-based comparison of methods for the meta-analysis of proportions and rates. [draft report]. Rockville, MD. Agency for Healthcare Research and Quality. 2012.
52 Trikalinos TA, Dahabreh IJ, Wallace BC, et al. A framework for rating the strength of methodological recommendations for systematic reviews and meta-analyses. [draft report]. Rockville, MD. Agency for Healthcare Research and Quality. 2012.