# Models and Estimation

Over several decades, many methods have been proposed for meta-analyzing data on performance of medical tests. The most theoretically motivated methodologies respect the multivariate nature of performance metrics, allow the true-positive rate (TPR, sensitivity) and false-positive rate (FPR, one minus specificity) to vary together across studies (because of a threshold effect or other reasons), and allow for between-study heterogeneity. The meta-analysis methods by Reitsma et al.8 (further augmented elsewhere42,43) and by Rutter and Gatsonis9 meet these desiderata. Reitsma’s method summarizes data as a “summary point”, that is, a summary TPR and a summary FPR. Rutter’s approach summarizes data by a “summary line” (equivalent to the hierarchical summary receiver operating characteristic curve when transformed into receiver operating characteristic [ROC] space), which describes how the average TPR changes with the average FPR. Choosing the most helpful summary is largely subjective and application-dependent, and in some situations the two summaries provide meaningful and complementary information.44

We focus on meta-analyses in which a summary point can be considered a helpful summary of test performance. We briefly review the Reitsma et al. random effects bivariate model and its augmentations42,43 for the meta-analysis of TPR and FPR of a single test, and describe its extension to two and three or more tests. We use M to denote the number of tests. In the following, we first describe models using the normal approximation to within-study variance, as historically these were developed first, and then present models that more accurately capture the discrete nature of the events (binomial distributions for one test and multinomial distributions for more than one test).45,46

## The Case of a Single Test

Consider a meta-analysis of K studies (indexed by k) evaluating a single test among individuals with and without a condition of interest (“disease”). Table 3 shows the true (unobserved, population) probabilities (denoted by π’s) of positive and negative test results in those with disease (D) and those without disease (D̄) in study k. By definition, the TPR of the test is equal to π_k , 1_^D^ , and the FPR of the test is equal to π_k , 1_^D¯^ .

Table 3 Notation for the probability of results for a single test in those with (D) and without disease (D̄ ) in study k

Test Results | Disease | No Disease
Negative (−) | π_k , 0_^D^ | π_k , 0_^D¯^
Positive (+) | π_k , 1_^D^ = T P R_k_ | π_k , 1_^D¯^ = F P R_k_

### Structural Model

We assume a bivariate random effects model.8 One can approximate the between-study variance using the normal distribution on logit-transformed data (approximate likelihood).^a^ We write the logistic transformation of TPR and FPR in study k:

a One can also use the normal approxim ation with the arcsine or probit transformation, or with untransformed data. Reitsma et al. used the canonical (logistic or logit) transformation, and this is the choice we follow here.

η_k_ = logit ( T P R_k_ ) = logit ( π_k , 1_^D^ ) 1

ξ_k_ = logit ( F P R_k_ ) = logit ( π_k , 1_^D¯^ ) 2

Across studies, the random effects for the true logit-transformed TPR and FPR are likely correlated, e.g., because of a threshold effect. We model this dependency using a bivariate normal distribution:

( η_k_ ξ_k_ ) ~ N ( ( H Ξ ) , T ) . 3

The means H and Ξ are the overall meta-analytic summaries of the logit-TPR and logit-FPR, respectively, and T is the between-study covariance matrix:

T = ( τ_η_^2^ ρ_η ξ_ τ_η_ τ_ξ_ τ_ξ_^2^ ) , 4

where the variances τ_η_^2^ and τ_ξ_^2^ represent the between-study heterogeneity in logit-transformed TPR and FPR, respectively, and ρ_ηξ_ is the corresponding between-study correlation.

### Observational Model: Normal (Approximate) Likelihood

In study k we obtain sample estimates of η_k_ and ξ_k_ based on the observed counts of test results in those with and without disease.

Table 4 gives the notation for the cross-classification of the results of a medical test in patients with and without disease in a single study. The p’s in

Table 4 Notation for observed counts and estimated probabilities for a single test in those with disease (D) and without disease (D̄ ) in study k

Test Results | Disease, Counts | Disease, Estimated Probabilities | No Disease, Counts | No Disease, Estimated Probabilities
Negative (−) | x_k , 0_^D^ | π^_k , 0_^D^ | x_k , 0_^D¯^ | π^_k , 0_^D¯^
Positive (+) | x_k , 1_^D^ | π^_k , 1_^D^ = T P R^_k_ | x_k , 1_^D¯^ | π^_k , 1_^D¯^ = F P R^_k_
Total | N_k_^D^ | 1 | N_k_^D¯^ | 1

Table 4 estimate the corresponding probabilities (π’s) in Table 3. For example, the estimate of the probability of a true positive result in study k is π^_k , 1_^D^ = x_k , 1_^D^ / N_k_^D^ , and correspondingly for the other probabilities. We estimate TPR by T P R^_k_ = π^_k , 1_^D^ , and FPR by F P R^_k_ = π^_k , 1_^D¯^ . Finally, the logit-transformed TPR and FPR in (1) and (2) are estimated by

η^_k_ = logit ( π^_k , 1_^D^ ) 5

and

ξ^_k_ = logit ( π^_k , 1_^D¯^ ) . 6

As mentioned above, TPR and FPR are proportions, so the binomial distribution is most suitable for modeling their within-study behavior (see below). However, it has not been uncommon to approximate the within-study distribution of the logit transformed proportions using normal distributions. Because TPR and FPR refer to disjoint sets of patients, η̂_k_ and ξ̂_k_ are independent conditional on study k:

η^_k_ ~ N ( η_k_ , σ_k η_^2^ ) , and 7

ξ^_k_ ~ N ( ξ_k_ , σ_k ξ_^2^ ) . 8

To facilitate later descriptions, we rewrite (7) and (8) as a single bivariate normal distribution

( η^_k_ ξ^_k_ ) ~ N ( ( η_k_ ξ_k_ ) , Σ_k_ ) , 9

where the within-study covariance matrix Σ_k_ has zero off-diagonal elements:

Σ_k_ = ( σ_k η_^2^ 0 σ_k ξ_^2^ ) . 10

The elements of Σ_k_ are considered known and are calculated from the data using the formulas in the Appendix. (This assumption is typically made, but without formal justification.)

### Observational Model—Binomial Likelihood

In place of (7) and (8) –or equivalently, (9) and (10)– we can use two independent binomials to model counts of test results in study k:

x_k , 1_^D^ ~ Bin ( T P R_k_ , N_k_^D^ ) 11

x_k , 1_^D¯^ ~ Bin ( F P R_k_ , N_k_^D¯^ ) 12

while retaining the structural model specified by (3) and (4).

## The Case of Two Tests

Consider a meta-analysis of two tests (indexed by m) and data from K studies. The outcome of each test is either negative (−) or positive (+). Table 5 gives the notation for the probability of each combination of test results in diseased patients and nondiseased participants in study k. Each of the 2^M^ = 2^2^ = 4 rows shows the corresponding proportion in the population.

Table 5 Notation for the probability of each combination of results in those with disease (D) and without disease (D̄) in study k – the case of two tests

Test 1 | Test 2 | Disease | No Disease
− | − | π_k , 00_^D^ | π_k , 00_^D¯^
− | + | π_k , 01_^D^ | π_k , 01_^D¯^
+ | − | π_k , 10_^D^ | π_k , 10_^D¯^
+ | + | π_k , 11_^D^ | π_k , 11_^D¯^

The marginal TPR and FPR in each test are:

T P R_k , 1_ = π_k , 1 •_^D^ = π_k , 10_^D^ + π_k , 11_^D^ , 13

T P R_k , 2_ = π_k , • 1_^D^ = π_k , 01_^D^ + π_k , 11_^D^ , 14

F P R_k , 1_ = π_k , 1 •_^D¯^ = π_k , 10_^D¯^ + π_k , 11_^D¯^ , 15

and

F P R_k , 2_ = π_k , • 1_^D¯^ = π_k , 01_^D¯^ + π_k , 11_^D¯^ . 16

In the equations, • indicates summation over the respective subscript. In addition, we define the “jointly true positive rate” (JTPR), and “jointly false positive rate” (JFPR):

JTPR_k_ = π_k , 11_^D^ 17

and

JFPR_k_ = π_k , 11_^D¯^ . 18

### Structural Model: TPR and FPR Parameterization

The sets of probabilities in the Disease and No Disease columns of Table 5 are each mutually exclusive and exhaustive and could be modeled with a multinomial distribution. Alternatively, we could re-express these parameters as functions of the sensitivities and specificities of each test and approximate the multinomial distribution using a multivariate normal distribution. As in the previous section, we work with logit-transformed probabilities. For study k and test m equations (1) and (2) become:

η_km_ = logit(TPR_k,_ _m_) 19

ξ_km_ = logit(FPR_k,_ _m_). 20

We also model the logit-JTPR, η_k*_, and logit-JFPR, ξ_k*_, which capture information on the agreement between the two tests in those with and without disease, respectively:

η_k *_ = logit ( π_k , 11_^D^ ) , and 21

ξ_k *_ = logit ( π_k , 11_^D¯^ ) . 22

By arranging quantities for the two tests in column vectors, we write

η_k_ = (η_k1_, η_k2_, η_k*_)′, and

ξ_k_ = (ξ_k1_, ξ_k2_, ξ_k*_)′.

with the prime (′) denoting transpose, bold symbols denoting vectors or matrices, and italics denoting scalars.

Across studies, the joint distribution of the random effects for the true logit-transformed TPRs, FPRs, JTPR and JFPR may involve correlation. We model this dependency using a six-dimensional normal distribution analogous to (3):

( η_k 1_ η_k 2_ η_k *_ ξ_k 1_ ξ_k 2_ ξ_k *_ ) = ( η_k_ ξ_k_ ) ~ N ( ( H Ξ ) , T ) , 23

where the means H = (H_1_, H_2_, H_*_)′ and Ξ = (Ξ_1_, Ξ_2_, Ξ_*_)′ are column vectors of the overall means of the respective quantities for the two tests, and T is a between-study covariance matrix, analogous to that in (4).

We propose an unstructured and a simplified structured specification for T:

#### Unstructured variant, T_A_

T_A_ = [ τ_η 1_^2^ ρ_η 1 η 2_ τ_η 1_ τ_η 2_ ρ_η 1 η *_ τ_η 1_ τ_η *_ ρ_η 1 ξ 1_ τ_η 1_ τ_ξ 1_ ρ_η 1 ξ 2_ τ_η 1_ τ_ξ 2_ ρ_η 1 ξ *_ τ_η 1_ τ_ξ *_ τ_η 2_^2^ ρ_η 2 η *_ τ_η 2_ τ_η *_ ρ_η 2 ξ 1_ τ_η 2_ τ_ξ 1_ ρ_η 2 ξ 2_ τ_η 2_ τ_ξ 2_ ρ_η 2 ξ *_ τ_η 2_ τ_ξ *_ τ_η *_^2^ ρ_η * ξ 1_ τ_η *_ τ_ξ 1_ ρ_η * ξ 2_ τ_η *_ τ_ξ 2_ ρ_η * ξ *_ τ_η *_ τ_ξ *_ τ_ξ 1_^2^ ρ_ξ 1 ξ 2_ τ_ξ 1_ τ_ξ 2_ ρ_ξ 1 ξ *_ τ_ξ 1_ τ_ξ *_ τ_ξ 2_^2^ ρ_ξ 2 ξ *_ τ_ξ 2_ τ_ξ *_ τ_ξ *_^2^ ] 24

In (24), T_A_ has 21 parameters that have to be estimated.

#### Structured variant, T_B_

For the case of two tests, we can impose structure (and reduce the number of parameters to be estimated to 13) by the following requirements:

a. All logit-TPRs have the same variance, τ_η_^2^
b. All logit-FPRs have the same variance, τ_ξ_^2^
c. The logit-JTPRs have the same variance, τ_η *_^2^
d. The logit-JFPRs have the same variance, τ_ξ *_^2^
e. The correlation between logit-TPRs in different tests is ρ_ηη_
f. The correlation between logit-FPRs in different tests is ρ_ξξ_
g. The correlation between logit-JTPR and logit-JFPR is ρ_η*ξ*_
h. The correlation between the logit-TPR and logit-FPR in the same test is ρ_ηξ_
i. The correlation between the logit-TPR and logit-FPR in different tests is ϱ_ηξ_
j. The correlation between the logit-TPR for each test and the logit-JTPR is ρ_ηη*_
k. The correlation between the logit-FPR for each test and the logit-JFPR is ρ_ξξ*_
l. The correlation between the logit-TPR for each test and the logit-JFPR is ρ_ηξ*_
m. The correlation between the logit-FPR for each test and the logit-JTPR is ρ_ξ* η_

T_B_ = [ τ_η_^2^ ρ_η η_ τ_η_^2^ ρ_η η *_ τ_η_ τ_η *_ ρ_η ξ_ τ_η_ τ_ξ_ ϱ_η ξ_ τ_η_ τ_ξ_ ρ_η ξ *_ τ_η_ τ_ξ *_ τ_η_^2^ ρ_η η *_ τ_η_ τ_η *_ ϱ_η ξ_ τ_η_ τ_ξ_ ρ_η ξ_ τ_η_ τ_ξ_ ρ_η ξ *_ τ_η_ τ_ξ *_ τ_η *_^2^ ρ_η * ξ_ τ_η *_ τ_ξ_ ρ_η * ξ_ τ_η *_ τ_ξ_ ρ_η * ξ *_ τ_η *_ τ_ξ *_ τ_ξ_^2^ ρ_ξ ξ_ τ_ξ_^2^ ρ_ξ ξ *_ τ_ξ_ τ_ξ *_ τ_ξ_^2^ ρ_ξ ξ *_ τ_ξ_ τ_ξ *_ τ_ξ *_^2^ ] . 25

### Structural Model: Probability Parameterization

Another, perhaps more direct approach, models the probabilities π_k_^D^ = ( π_k , 00_^D^ , π_k , 01_^D^ , π_k , 10_^D^ , π_k , 11_^D^ ) and π_k_^D¯^ = ( π_k , 00_^D¯^ , π_k , 01_^D¯^ , π_k , 10_^D¯^ , π_k , 11_^D¯^ ) directly, rather than re-expressed in terms of sensitivity, specificity and joint positivity. One could work with the logits of these probabilities and reformulate the multivariate normal model in terms of them or one could proceed to model the probabilities themselves in the form of a Dirichlet distribution. The resulting parameter estimates could then be re-expressed in terms of TPRs and FPRs, if desired, either directly through transformations of MCMC simulations from Bayesian analyses or using the delta method with likelihood analyses. We leave this for future work.

### Observational Model: Multivariate Normal (Approximate) Likelihood

We calculate sample estimates for the quantities in the structural model using the observed counts in Table 6. For each combination of test results, the estimate of the population proportion is

π^_k_^D^ = x_k_^D^ / N_k_^D^ 26

(we have suppressed the indices corresponding to the rows in Table 6); N_k_^D^ is the total number of those with disease. (For notational simplicity we assume that both tests are applied to all patients, and thus N_k , 1_^D^ = N_k , 2_^D^ = N_k_^D^ .) The corresponding notation for those without disease replaces D with D̄. We estimate the sensitivity and specificity of test m in study k by the replacing true probabilities (π’s) with the respective sample estimates (π̂’s) in (13) through (16); and the logit-transformed TPR, FPR, JTPR and JFPR by

η^_k m_ = logit ( T P R^_k , m_ ) , 27

ξ^_k m_ = logit ( F P R^_k , m_ ) , 28

η^ * = logit ( π^_k , 11_^D^ ) , and 29

ξ^_k *_ = logit ( π^_k , 11_^D¯^ ) . 30

Table 6 Notation for observed counts and estimated probabilities in those with disease (D) and without disease (D̄) in study k – the case of two tests

Test 1 | Test 2 | Disease, Counts | Disease, Estimated Probabilities | No Disease, Counts | No Disease, Estimated Probabilities
− | − | x_k , 00_^D^ | π^_k , 00_^D^ | x_k , 00_^D¯^ | π^_k , 00_^D¯^
− | + | x_k , 01_^D^ | π^_k , 01_^D^ | x_k , 01_^D¯^ | π^_k , 01_^D¯^
+ | − | x_k , 10_^D^ | π^_k , 10_^D^ | x_k , 10_^D¯^ | π^_k , 10_^D¯^
+ | + | x_k , 11_^D^ | π^_k , 11_^D^ | x_k , 11_^D¯^ | π^_k , 11_^D¯^
Totals | | N_k_^D^ | 1 | N_k_^D¯^ | 1

We assume that both tests are applied to all patients, and thus N_k , 1_^D^ = N_k , 2_^D^ = N_k_^D^ .

We model within-study variability in study k using a multivariate normal distribution in a manner analogous to (9). More explicitly,

( η^_k 1_ η^_k 2_ η^_k *_ ξ^_k 1_ ξ^_k 2_ ξ^_k *_ ) = ( η^_k_ ξ^_k_ ) ~ N ( ( η_k_ ξ_k_ ) , Σ_k_ ) . 31

The within-study covariance matrices Σ_k_ in (31) include the within-study correlations between the logit-transformed TPRs, FPRs, JTPR and JFPR. The elements of η̂_k_ are correlated because they pertain to the same patients (those with disease). The elements of ξ̂_k_ are correlated because they are calculated in the same patients (those without disease). However, η̂_k_ is not correlated with ξ̂_k_ because they are calculated in disjoint samples. Thus, Σ_k_ is a block-diagonal matrix:

Σ_k_ = [ Σ_k η_ 0 Σ_k ξ_ ] = [ σ_k η 1_^2^ σ_k η 12_ σ_k η 1 *_ σ_k η 2_^2^ σ_k η 2 *_ σ_k η * *_^2^ 0 0 σ_k ξ 1_^2^ σ_k ξ 12_ σ_k ξ 1 *_ σ_k ξ 2_^2^ σ_k ξ 2 *_ σ_k ξ * *_^2^ ] , 32

where Σ_kη_ and Σ_kξ_ are the 3 × 3 covariance matrices of the logit-transformed metrics in those with disease and those without disease, respectively, and 0 a 3 × 3 matrix of zeros. The elements of Σ_k_ are considered known and are calculated from the data using the formulas in the Appendix. The analogy between (9) and (31), and between (10) and (32) is clear.

If the tests have not been applied in the same patients (i.e., the comparative studies used a parallel design) (32) becomes a diagonal matrix, i.e., a matrix with all off-diagonal elements equal to zero.

### Observational Model: Multinomial Likelihood

Alternatively, one can use the multinomial distribution to model the cross-classification of the results of two or more tests. Specifically, the column vectors of counts x^D^ = ( x_k 0 ⋯ 0_^D^ , … , x_k 1 ⋯ 1_^D^ )^′^ and x^D¯^ = ( x_k 0 ⋯ 0_^D¯^ , … , x_k 1 ⋯ 1_^D¯^ )^′^ follow multinomial distributions:

x^D^ ~ M ( N_k_^D^ , π_k_^D^ ) , 33

and

x^D¯^ ~ M ( N_k_^D¯^ , π_k_^D¯^ ) . 34

The estimates of the true probabilities π_k_^D^ = ( π_k 0 ⋯ 0_^D^ , … , π_k 1 ⋯ 1_^D^ )^′^ and π_k_^D¯^ = ( π_k 0 ⋯ 0_^D¯^ , … , π_k 1 ⋯ 1_^D¯^ )^′^ are π̂^D^ and π̂^D̄^, respectively, with elements defined in (26) (and its counterpart for those without disease).

As above, if the tests have not been applied in the same patients (i.e., the comparative studies used a parallel design) (33) and (34) become sets of independent binomials.

## The Case of Three or More Tests

One can extend the models to M > 2 tests that have been applied in the same patients, but some care is required to ensure that the resulting model has enough parameters to represent the probabilities of all the possible outcomes in cross-classified data. The number of parameters is not the only challenge, as we discuss below.

### Number of Parameters

Because the number of parameters needed to fully specify the test results among both diseased and nondiseased individuals is 2^M^ − 1, the total number of parameters for a fully specified model increases very rapidly. We need:

- 2^M^ − 1 parameters to model the probabilities (or functions of probabilities) in those with disease
- 2^M^ − 1 parameters in those without the disease
- (2^M+1^ − 2)(2^M+1^ − 1)/2 parameters to model between-study variances and covariances, assuming the unstructured covariance matrix T_A_ in (24), for a total of (2^M+1^ − 2)+[(2^M+1^ − 2)(2^M+1^ − 1)/2] parameters.

As per Sections 3.1 and 3.2, one needs 5 and 27 parameters for one and two tests, respectively. For three and four tests one needs 119 and 495 parameters, respectively! Numerical difficulties arise both in unstructured parameterizations because of the large number of parameters and in structured parameterizations in which it may be difficult to enforce positive definiteness of the covariance matrices during optimization.

As mentioned already, several parameterizations of the probabilities are possible. One model uses logits of the 2^M^ − 1 probabilities of individual test combinations in both diseased and nondiseased individuals. Another uses the M logit-TPRs together with the logits of other suitable functions of the individual probabilities, as we did for the case of two tests. For illustration, when M = 3, 2^M^ − 1 = 7, and the additional four functions could be the probability that Test 1 and Test 2 are positive, the probability that Test 1 and Test 3 are positive, the probability that Test 2 and Test 3 are positive, and the probability that all three tests are positive. (In a particular application, the choice of such functions should take into account the likely probabilities, so as to minimize difficulties with small probabilities and small cell counts.)

For the case of three or more tests, the practical consequences of such representations are unclear. In practice, it is unlikely that a systematic review would find completely cross-classified data on more than two tests.

Handling the observational model is less complex presuming the multinomial likelihood is used. Within each group of diseased or nondiseased individuals, the counts of combinations of positive and negative test results on all the tests forms a cross-classification that can be represented by a multinomial distribution. The approximate normal likelihood becomes too complex when M>3.