# Incomplete or Missing Data

In practice, not all studies in a meta-analysis report counts on all combinations of test results in diseased and nondiseased participants. In the example, even with only two tests, the level of detail varies substantially. For some studies we can construct the full cross-classification for both TPR and FPR, for some we can construct the cross-classification for TPR but not FPR or vice versa; some studies report only the estimated TPRs and FPRs of the tests, and others report an intermediate level of detail. In principle, it is desirable to incorporate all available suitable evidence, perhaps including results from studies that evaluated only a single test. And if the total number of tests to be analyzed is greater than two, it is likely that many studies will have evaluated only two of the tests. We can describe many patterns of missingness, but we comment on the following three:

## Information To Extract Cross-Classification Counts Is Not Reported

Often studies report information on the TPR or the FPR of each test, but do not provide data to reconstruct the cross-classification of test results. Assuming that data are missing at random, one could proceed with imputation of the missing within-study correlations between the quantities of interest, using information from the observed correlations from studies with complete data. In performing the imputation, one must ensure the positive definiteness of the covariance matrix. Another option imputes the missing counts directly. This is the approach taken in the analysis of the example in this work.

## A Subset of Studies Reports Only on Diseased or Only on Nondiseased Individuals

If information is missing at random, one obtains unbiased estimates by optimizing the appropriate likelihood omitting contributions from the missing subsets.

## Some Studies Do Not Report Results From Each Test

If information is missing at random, one again optimizes the likelihood of the observed data omitting the missing tests.