# Illustrative Example

We examine the screening accuracy of second-trimester ultrasound markers in detecting liveborn infants with trisomy 21 (Down syndrome). Briefly, trisomy 21 is a clinically important chromosomal abnormality whose frequency is strongly associated with maternal age (more common in older mothers). Infants with trisomy 21 manifest mental retardation and have high risk of congenital structural defects.10 Until the mid-1980s maternal age was the only predictor for trisomy 21. Since then, biochemical measurements in maternal plasma (alpha-fetoprotein, human chorionic gonadotrophin, inhibin A and estriol), as well as many ultrasonographic markers in the first and second trimester, have been examined as screening tests. Mothers and fetuses identified by a positive screening test result are typically offered a definitive diagnosis via amniocentesis, an invasive diagnostic test.

As an illustration, we use information from 11 studies combined in a published meta-analysis that examined the screening accuracy of seven ultrasonographic markers or their combination in detecting trisomy 21 in liveborn infants.11 We focus on two such markers, shortened humerus (arm bone), and shortened femur (thigh bone) of the fetus. Two of the authors (TAT and DCH) extracted information from the full text of the pertinent articles on the provenance of the paper (first author, year of publication), the definition of positive screening tests, and cross-classification counts for the presence or absence of each marker among infants with and without trisomy 21. The extractors discussed and reconciled all results and also discussed them with a third author (CHS).

We emphasize that this example is for illustration only, and the analyses presented here should not be used for decisionmaking. Current prenatal screening programs do not rely on isolated markers, but combine sequential biochemical and ultrasound testing. Further, prenatal screening programs also aim to detect trisomy 13 (Patau syndrome), trisomy 18 (Edwards syndrome) and neural tube defects.10 In addition, new screening methods sequence cell-free fetal DNA circulating in maternal plasma and are summarized by Palomaki et al.12

Table 1 and Table 2 show the extracted data. Table 1 shows 11 studies that reported counts of the results of each test.13–23 Five studies reported sufficient information to calculate counts of combinations of test results among infants with trisomy 21 and among healthy infants,13–16,20 1 study reported sufficient information to calculate counts of combinations of test results in trisomy 21 infants only,23 and the remaining 5 reported only separate counts for the two tests.17–19,21,22 Three studies measured humerus in a subset of healthy infants with femur measurements.17–19 Table 2 shows 19 additional studies (reported in 18 publications24–41) that measured shortened femur only. No studies measured shortened humerus only.

Table 1 Cross-classification of counts of shortened femur or shortened humerus among infants with trisomy 21 and healthy infants (studies reporting both tests)

Study Year [reference] | Design | Positive Test (ratio of observed to expected length) | Trisomy 21 | | | | | | | Healthy
Study Year [reference] | Design | Positive Test (ratio of observed to expected length) | N | H+ | F+ | H+/F+ | H+/F− | H−/F+ | H−/F− | N | H+ | F+ | H+/F+ | H+/F− | H−/F+ | H−/F−
Benacerraf 1991 13 | Case-control | H: <0.90; F: <0.91 | 24 | 12 | 10 | 9 | 3 | 1 | 11 | 400 | 25 | 40 | 19 | 6 | 21 | 354
Benacerraf 1992 14 | Case-control | H: <0.90; F: <0.91 | 32 | 17 | 23 | 17 | 0 | 6 | 9 | 588 | 34 | 63 | 23 | 11 | 40 | 514
Benacerraf 1994 15 | Case-control | H: <0.90; F: <0.91 | 45 | 20 | 22 | 20 | 0 | 2 | 23 | 106 | 3 | 4 | 1 | 2 | 3 | 100
Biagiotti 1994 16 | Case-control | H: <0.90; F: <0.91 | 27 | 10 | 13 | 10 | 0 | 3 | 14 | 500 | 60 | 60 | 31 | 29 | 29 | 411
Bromley 1997 17 | Case-control | H: <0.90; F: ≤0.91 | 53 | 19 | 25 | – | – | – | – | 177 (149)^*^ | 5 | 14 | – | – | – | –
Johnson 1995 18 | Case-control | H: ≤0.90; F: ≤0.90 | 36 | 8 | 15 | – | – | – | – | 794 (486)^†^ | 25 | 127 | – | – | – | –
Lockwood 1993 19 | Prospective | [Observed minus expected, mm] H <−3.6; F <−3.4 | 42 | 6 | 6 | – | – | – | – | 4874 (2775)^‡^ | 111 | 161 | – | – | – | –
Nyberg 1993 20 | Case-control | H: ≤0.89; F: ≤0.91 | 45 | 11 | 11 | 8 | 3 | 3 | 31 | 942 | 42 | 44 | 15 | 27 | 29 | 871
Nyberg 1998 21 | Case-control | H: ≤0.89; F: ≤0.91 | 142 | 27 | 30 | – | – | – | – | 930 | 11 | 43 | – | – | – | –
Rodis 1991 22 | Case-control | [Percentile of measurement] H <5^th^; F <5^th^ | 11 | 7 | 2 | – | – | – | – | 1470 | 74 | 74 | – | – | – | –
Vintzileos 1996 23 | Prospective | H: <0.89; F: <0.88 | 22 | 10 | 5 | 4 | 6 | 1 | 11 | 493 | 49 | 50 | – | – | – | –

F[+|−] = shortened femur [present | absent]; H[+|−] = shortened humerus [present | absent]; N = total (per disease category)

* Total 177 for femur, and 149 for humerus. All those tested for humerus were also tested for femur.

† Total 794 for femur, and 486 for humerus. All those tested for humerus were also tested for femur.

‡ Total 4874 for femur, and 2775 for humerus. All those tested for humerus were also tested for femur.

Table 2 Number of counts of shortened femur among infants with trisomy 21 and healthy infants (studies of shortened femur only)

Study year [reference] | Design | Positive test (ratio of observed to expected length) | Trisomy 21 | | Healthy
Study year [reference] | Design | Positive test (ratio of observed to expected length) | N | F+ | N | F+
Benacerraf 1989 28 | Case-control | <0.91 | 20 | 7 | 3480 (709)^*^ | 28
Brumfield 1989 29 | Case-control | [BPD/FL≥1.80] | 15 | 6 | 45 | 1
Campbell 1994 24 | Prospective | [BPD/FL≥1.5 SD in controls] | 6 | 3 | 264 | 20
Cuckle 1989 26 | Case-control | ≤0.90 | 83 | 20 | 1340 | 84
Dicke 1989 27 | Case-control | <0.91 | 33 | 5 | 177 | 18
Ginsberg 1990 25 | Case-control | [BPD/FL>1.5 SD in controls] | 12 (11)^†^ | 5 | 212 | 14
Grandjean 1995 30 | Prospective | <0.91 | 34 | 15 | 2763 | 495
Grist 1990 32 | Prospective | ≤0.90 | 6 | 3 | 428 | 28
Hill 1989 34 | Case-control | ≤0.91 | 22 | 11 | 286 | 43
Johnson 1993 31 | Prospective | [FL/Foot length≤0.90] | 14 | 10 | 331 | 31
LaFollette 1989 33 | Case-control | ≤0.91 | 30 | 4 | 229 | 27
Lockwood 1987 (New Haven) 35 | Case-control | [BPD/FL>1.5 SD in controls] | 35 | 18 | 349 | 26
Lockwood 1987 (Boston) 35 | Case-control | [BPD/FL>1.5 SD in controls] | 20 | 14 | 195 | 9
Lynch 1989 41 | Case-control | [BPD/FL>1.5 SD in controls] | 9 | 5 | 9 | 5
Marquette 1990 38 | Case-control | [BPD/FL>1.5 SD in controls] | 31 | 3 | 155 | 14
Nyberg 1990 39 | Case-control | ≤0.91 | 49 | 7 | 572 | 35
Nyberg 1995 37 | Prospective | ≤0.91 | 18 | 5 | 232 | 14
Shah 1990 40 | Case-control | [BPD/FL; threshold not stated] | 17 | 3 | 17 | 1
Verdin 1998 36 | Case-control | [>97.5 percentile of BPD/FL in controls] | 11 | 6 | 449 | 5

BPD = biparietal diameter; F+ = shortened femur; FL = observed femoral length; SD = standard deviation.

* 3,480 were included, 709 were analyzed for shortened femur.

† 12 were included, 11 were analyzed for shortened femur.