# Discussion

We propose models for the joint (multivariate) meta-analysis of M ≥ 2 diagnostic tests. The models are applicable when the tests are applied in the same patients and a substantial number of studies report data on the cross-classification of results from several tests, and for examples in which it is helpful to summarize study accuracy with a “summary point” (such as summary sensitivity and specificity), rather than a “summary line” (such as a hierarchical summary receiver operating characteristic curve). We derive formulas for calculating within-study covariances from data reported in the studies themselves. We show in an applied example that the developed methods can result in tighter confidence intervals for comparisons between sensitivities or false-positive rates of different tests than those from separate meta-analyses for each test.

True comparative accuracy studies involve a network of different diagnostic accuracy studies that include fully cross-classified data from crossover studies, data from crossover studies reported as separate 2 × 2 tables, and data from parallel test studies that examine all or a subset of the potential index tests. The herein described models can form the basis for network meta-analysis of test accuracy. For example, the case of three or four tests is essentially a case of network meta-analysis. Nevertheless, for a more general solution to the meta-analysis of networks of diagnostic accuracy studies, the herein presented work should be extended to incorporate all of the data structures, respect their constraints and simultaneously estimate all parameters, while respecting consistency equations that arise when the network contains three or more tests that are not all compared in each study.

We hypothesize that most studies of diagnostic accuracy that assess two or more tests in the same patients do not report sufficient data to extract the cross-tabulations of test results as in Table 5. If this is true, only separate meta-analyses are possible. Authors of primary studies of diagnostic accuracy should be encouraged to report such information clearly. In our work with the illustrative example, the extraction of counts for cross-classified test results was challenging. For example, Biagiotti et al.16 reported cumulative counts of test positives for shortened humerus, shortened femur and for both tests combined using several thresholds. To reconstruct the equivalent of Table 5 for the thresholds of interest (ratio of observed to expected length <0.90 for humerus and <0.91 for femur), we had to employ mixed integer linear programming (details available from the authors on request). Even so, we could not extract cross-tabulation counts from five studies in the trisomy 21 group, and from six studies in the healthy group.

In the application, when the focus is on estimates of the summary TPRs or summary FPRs, the payoff of multivariate analyses was modest at best, in that the differences in the summary estimates and confidence/credible intervals from separate meta-analyses for each test were not that pronounced. For the models presented here, the summary point estimates from separate meta-analyses will be the same as from joint meta-analyses if (a) the within study covariances are zero, or (b) if the within-study covariance matrices are all equal (that is ∑k = ∑ for all k).50 The former is unlikely for diagnostic tests, because we can reasonably expect that results obtained from tests applied to the same patients will be positively correlated. Therefore, for meta-analysis of diagnostic tests the point estimates will differ when the within-study covariance matrices are most dissimilar across studies. However, the variances of the summary estimates are always affected.

The most pronounced differences between separate and joint meta-analyses are observed when one estimates comparative diagnostic accuracy. We see this as a manifestation of the theoretical advantages of the joint meta-analyses. First, the joint meta-analyses utilize all the information in the cross-tabulation of the test results, and this translates into smaller standard errors compared with separate meta-analyses. Second, with joint meta-analyses one can obtain simultaneous confidence intervals that control the type I error for all possible linear combinations of summary estimates, as described in (40).47 Third, when calculating comparative test accuracy, the joint meta-analyses respect the grouping of data by study. In contrast, separate meta-analyses rely on differences of marginal estimates; that is, they first average across studies and then compare the averages. As in meta-analyses of treatment effects, the latter approach can result in biased estimates (in some way analogous to Simpson’s paradox).

Already with two tests, transforming the parameters to the logit scale introduces a complication: the sum of the probabilities recovered from the logit-scale parameters is not guaranteed to be 1. One can avoid this complication by constrained optimization or by using parameters in the probability scale and a Dirichlet distribution for the random effects. Further research will be necessary to determine whether a Dirichlet distribution can accommodate sums of probabilities such as TPRs and FPRs as parameters, or only the individual probabilities.

Nevertheless, our work demonstrates complexities introduced by simultaneous consideration of multiple diagnostic tests that are not apparent in treatments of diagnostic test models which focus on a single test. First, while sensitivity and specificity completely describe the model parameters for a single test, they fail to do so once a second test is introduced. Then, it becomes necessary to consider the joint probability of the two tests in addition to the marginal probabilities of each. With additional tests, the need for extra parameters grows rapidly and it is not clear at all which are the most clinically important parameterizations.

Second, the number of cross-classifications grows rapidly with more tests, thus increasing the chance of combinations of test results with small counts. When some counts are small, the normal likelihood becomes suboptimal46,51 and multinomial observational distributions are preferred. Moreover, not only are the observed counts small but the cell probabilities also may become extremely small and so the asymptotic normality of the random effects distribution may no longer hold either. Random effects will also be imprecisely estimated when the number of participants is small and outliers will become more of an issue, inflating between-study variances and inflating prediction ellipses.

Third, the exponentially exploding number of parameters will require structured correlation matrices for model identifiability and numerical convergence. We have suggested one such structure, but even its simple form did not always permit our models to be estimable. More experience with these models is needed to resolve both numerical and conceptual issues for appropriate structures.

Fourth, as the number of tests increases, the likelihood that each patient will receive each test and have a recorded result becomes unlikely. Missing data will then become the norm, rather than the exception. Such missing data may be random or structural when certain tests are not ordered. Assumptions about the missing data mechanism become crucial with large amounts of missing data and with nearly empty cells. Our assumption that data are missing at random will hold only in special situations. These certainly do not include sequences of tests where test ordering is related to prior knowledge about health status.

Fifth, while comparative accuracy studies should rightly be set up so that patients receive each test in order to reduce biases and ensure the clinical relevance of the resulting inferences, such designs require strict protocols to ensure validity. Many of these issues are covered by items in the QUADAS study quality and STARD reporting quality instruments including prospective and consecutive data collection, avoidance of verification bias, blinding of readers to test and gold standard results and control of the time between test administrations. As the number of tests grows, quality control becomes more difficult and differences may begin to influence test results.

Finally, in the field of diagnostic accuracy it is hard to imagine a topic where exploration of heterogeneity with covariates is not needed. In principle, adding covariates to the current models is straightforward: one simply has to substitute linear equations of the covariates in the place of the means at the structural model. This will increase the number of parameters further. An additional complication stems from the different parameterizations of the probabilities in the structural model. For example, the interpretation of the coefficients for covariates will be very different for parameterizations based on sums of probabilities (e.g., TPRs and FPRs) versus a direct parameterization of the probabilities themselves. It is not clear how one should judge the appropriateness of the various parameterizations.

So should one use separate or joint meta-analysis for analyzing paired diagnostic accuracy data? This work introduces one approach and is not sufficient for making general methodological recommendations. In theory, the decision for performing separate versus joint meta-analyses depends on the underlying assumptions that the researcher is prepared to make about the data. Ideally, these decisions should be made early in the analysis, and not after an examination of the data. In some instances alternative analyses will yield similar results; in other instances they may not. The fact that we observed differences in comparative test accuracy in a single example is not a strong basis for recommending general use.

More generally but in the same vein, methodological recommendations address the problem of choosing between alternative methodologies, and developing them should be approached as a decision problem.52 In brief, one must define the decision context, which includes specifying: (a) the perspective from which the problem is approached (e.g., recommendations for specialists who perform publicly funded research may have to set a much higher bar than recommendations for the meta-analysis community, which may want to set pragmatic minimum standards); (b) all reasonable alternative choices; (c) the type of problems to which the recommendation applies; (d) the characteristics or quantities (utilities) that will be used in making a decision, and their relative weights if more than one exist. These represent not only the scientific rigor of each alternative but also issues such as the feasibility of performing an analysis without access to statistical expertise or specialized software, and other concerns. Subsequently, one must examine theoretical arguments, results from simulation analyses, or empirical data, as applicable, and be transparent on how the recommendation is reached. Pending an adequate exploration of this decision problem in their setting, our opinion is that meta-analysts facing problems such the one analyzed here should consider performing joint meta-analysis, if only as a sensitivity analysis.