# Background

The value of diagnostic testing for patient management ultimately derives from its effect on patient-relevant outcomes. Testing primarily affects outcomes by indirect means, influencing downstream patient management decisions, including decisions for further testing, and administration or choice of treatment. Thus, the relative accuracy of diagnostic tests has considerable importance. The ideal study compares the effectiveness and safety of complete test-and-treat strategies, but such studies are exceedingly rare.1 Instead, one has to assemble data on effectiveness and safety from various sources,2 including studies of test performance (test accuracy) and studies of the effects of interventions. For this reason, meta-analysis of accuracy plays a key role in evaluations of medical tests,3 although it does not directly determine the comparative effectiveness and safety of test-and-treat strategies.4–7

Two key characteristics of a diagnostic test, sensitivity and specificity, depend on its threshold for classifying an outcome as positive. If high values are “positive”, lowering the threshold increases sensitivity at the expense of specificity; increasing the threshold moves the measures in the opposite directions. Recent statistical work has focused on developing bivariate analytic techniques that jointly model sensitivity and specificity in order to account for this inherent negative correlation.8,9 Such models have focused on a single test.

To compare of the accuracy of two (or more) tests, analysts typically take one of two approaches: (a) perform a separate meta-analysis for each test and compare the meta-analytic summaries; or (b) perform a meta-regression using the type of test as a categorical predictor. Both methods assume that all individuals studied are independently sampled (i.e., that the tests study two distinct sets of individuals, each containing individuals with disease and individuals without disease). But when the same individuals receive both tests, their results are correlated. A valid statistical model must account for this dependence. Because the two common approaches do not take these correlations into account, neither is a valid method for comparing tests performed on the same individuals.

In broad terms, diagnostic accuracy studies can be noncomparative, when they assess one index test at a given setting, or comparative, when they assess the performance of two or more tests. Estimates of comparative test accuracy can be obtained from either category of studies. Estimates from the former group are confounded by study setting, whereas estimates from the latter group are not. Further, comparative studies can have paired (or “crossover”) designs (where each test is applied to the same patients) or parallel designs (where each test is applied in disjoint sets of patients, e.g., using random allocation or other means). A paired design is statistically much more efficient, in that one needs much smaller sample sizes to detect a given difference in test accuracy, compared with a parallel design.

Reflecting this, data from studies that evaluate two tests can take more complicated forms. A “crossover” study, which obtains results on both tests for each individual, may report the sensitivity and specificity (e.g., as a 2 × 2 table) for each test separately, and not the full cross-classifications. Or one set of individuals may receive both tests, a second subset only the first test, and a third subset only the second test. Yet another study design randomly assigns individuals to the two tests or, without randomization, administers each test to separate sets of individuals (including those with disease and those without disease). This work focuses primarily on the case in which the same individuals receive both tests and the results are cross-classified. It briefly discusses some of the other forms, which represent minor modifications to the models for assessing studies with paired designs.

Jointly analyzing the true- and false-positive rate (equivalently, sensitivity and one minus specificity) of two diagnostic tests made on the same individuals requires multivariate models, to account for the relation between the outcomes of the two tests in patients with disease and in patients without disease within studies and variation in those outcomes among studies. In this work, we derive a model that accounts for such relations. The model can be fitted to data that report totals of true and false positive and negative results for each test and for each combination of tests. We provide algorithms for maximizing the resulting likelihood and for calculating asymptotically correct confidence intervals for summary estimates and for differences between summary estimates. We also provide algorithms for fitting models with Markov Chain Monte Carlo (MCMC) methods in a Bayesian framework.

The remainder of the work is organized around a motivating example from a meta-analysis of two second-trimester ultrasonographic tests that screen for trisomy 21 (Down syndrome). We first describe the example, and then we present the model for two tests and extensions to more than two tests. We then proceed with a description of estimation and inference, and a comment on some patterns of missing data (at the study level). We then present an analysis of the data, and we conclude with a discussion of the method and its applications.