# Formulas for Within-Study Covariance Matrices and for 1.96-Standard Error Volumes

## Variances for logit-transformed sensitivities and false positive rates for bivariate meta-analysis (single test)

See Table 3 in the main report for notation. The within-study covariance ∑_k_ in study k has zero off-diagonal elements, because sensitivity and specificity are calculated in independent groups.

Σ_k_ = ( σ_k η_^2^ 0 σ_k ξ_^2^ ) ,

with

σ_k η_^2^ = (1)/(N_k_^D^ p_k 1_^D^ ( 1 - p_k 1_^D^ )) ,

and

σ_k ξ_^2^ = (1)/(N_k_^D¯^ p_k 1_^D¯^ ( 1 - p_k 1_^D¯^ )) ,

## Variances for logit-transformed sensitivities and false positive rates for the joint multivariate meta-analysis of two tests

Application of the multivariate delta method yields the following formulas. (The notation [m:1] indicates the sum over all patterns in which the outcome on test m is 1).

Variance of logit TPR in study k for test m:

σ_k , η m_^2^ = (1)/(N_k_^D^ π^_k [ m : 1 ]_^D^ ( 1 - π^_k [ m : 1 ]_^D^ ))

Variance of logit JTPR in study k:

σ_k , η *_^2^ = (1)/(N_k_^D^ π^_k , 11_^D^ ( 1 - π^_k , 11_^D^ ))

Variance for logit FPR in study k for test m:

σ_k , ξ m_^2^ = (1)/(N_k_^D¯^ π^_k [ m : 1 ]_^D¯^ ( 1 - π^_k [ m : 1 ]_^D¯^ ))

Variance for logit JFPR in study k:

σ_k , ξ *_^2^ = (1)/(N_k_^D¯^ π^_k , 11_^D¯^ ( 1 - π^_k , 11_^D¯^ ))

Covariance between logit TPRs of tests m and t in study k:

σ_k , η m η t_ = (π^_k [ m : 1 , t : 1 ]_^D^ - π^_k [ m : 1 ]_^D^ π^_k [ t : 1 ]_^D^)/(N_k_^D^ π^_k [ m : 1 ]_^D^ ( 1 - π^_k [ m : 1 ]_^D^ ) π^_k [ t ; 1 ]_^D^ ( 1 - π^_k [ t : 1 ]_^D^ ))

Covariance between logit FPRs of tests m and t in study k:

σ_k , ξ m ξ t_ = (π^_k [ m : 1 , t : 1 ]_^D¯^ - π^_k [ m : 1 ]_^D¯^ π^_k [ t : 1 ]_^D¯^)/(N_k_^D¯^ π^_k [ m : 1 ]_^D¯^ ( 1 - π^_k [ m : 1 ]_^D¯^ ) π^_k [ t : 1 ]_^D¯^ ( 1 - π^_k [ t : 1 ]_^D¯^ ))

Covariance between logit TPR of test m and logit-JTPR in study k:

σ_k , η m η *_ = (1)/(N_k_^D^ π^_k [ m : 1 ]_^D^ ( 1 - π^_k , 11_^D^ ))

Covariance between logit FPR of test m and logit-JFPR in study k:

σ_k , ξ m ξ *_ = (1)/(N_k_^D¯^ π^_k [ m : 1 ]_^D¯^ ( 1 - π^_k , 11_^D¯^ ))

### Formulas for calculating 1.96-standard-error volumes

Let t_1_,…,t_M_ be the lengths of the half axes of an ellipsoid of dimension M that corresponds to the contour surface of one standard error. The volume V_M_ included in this one-standard-error surface is calculated by integration. We calculated the first three integrals. (In the following three formulas π = 3.14159...)

V_2_ = π t_1_ t_2_ V_3_ = (4)/(3) π t_1_ t_2_ t_3_ V_4_ = (1)/(2) π^2^ t_1_ t_2_ t_3_ t_4_

For a covariance matrix C we have to calculate the lengths of the half axes for the one-standard-error contour ellipsoid. Rotation to an orthonormal basis automatically provides the lengths of the half axes; these are the square roots of the eigenvalues λ_1_,…,λ_M_ of C. So set t_m_ = sqrt(λ_m_) in the formulas above. The 1.96-standard-error volume uncorrected for multiple comparisons is

(z_0.025_)^M^V_M_,

With z_α/2_ = 1.96 denoting the upper α/2 percentile of the standard normal distribution. For example in the main report, Table 11 the volumes in rows (b) and (c) pertain to four-dimensional models and were calculated using the formula above, for M = 4. The confidence volume in row (a) corresponds to two independent bivariate models. It is calculated as the product of the confidence volumes of dimension 2, one for each bivariate model.