# Analysis of the Example

As is typical for screening tests, individual studies have chosen thresholds to attain primarily low FPR (ranging from less than 1% to 18% for both tests, except for a single study with shortened femur with an FPR of 55%), with TPRs that range from 10 percent to 72 percent for both tests (Figure 1).

Figure 1 Observed sensitivities and false-positive rates for the two tests in the example

Note: Markers denote studies (circles: shortened humerus; squares: shortened femur). In the rightmost plot, lines connect test results in the same patients (from paired studies).

Figure 1 contains three graphs, one depicting the sensitivity and false-positive rate for the use of the shortened humerus in detecting trisomy 21 (Down syndrome) in liveborn infants, another depicting the same rates when the shortened femur is used, and a third where results on shortened humerus and shortened femur in the same patients are connected with lines. The sensitivities and false positive rates in both graphs are similar, with the sensitivities ranging from less than 0.1 to approximately 0.8 and the false positive rates ranging from zero to less than 0.6.

Figure 2 shows scatter plots of logit-transformed TPR and FPR for the studies in the example. Most plots give the impression of positive correlation between the estimated quantities. For descriptive purposes we calculated empirical Spearman correlation coefficients, which corroborate the visual impressions Table 7). This informal exploration lends support to the notion that the joint multivariate meta-analysis of the two tests will take into account information that separate bivariate meta-analyses would ignore.

Figure 2 Scatter plots of η̂’s and ξ̂’s in the example

Note: Circles denote paired test studies. In the η̂_2_ vs. ξ̂_2_ plot, “x” marks denote studies of shortened femur only. The asterisk (“*”) marks a study where the FPR is 55 percent (logit-FPR is 0.20) but has been relocated to lie in the plotted region. The range of the axes in the scatter plots is approximately 3 units in the logit scale, and the aspect ratio has been kept to 1 to facilitate visual assessments. FPR: false-positive rate (one minus specificity); TPR: true-positive rate (sensitivity).

Figure 2 contains six scatter plots of eta-hat and xi-hat values for logit-transformed true-positive rates (TPRs, or sensitivities) and false-positive rates (FPRs, or one minus specificity values) for the eleven studies in the sample. Most plots suggest a positive correlation. In each plot, circles denote studies. Each axis spans 3 units in the logit scale.

Table 7 Empirical correlations between η̂’s and ξ̂’s in the example

| η̂ _1_ | η̂ _2_ | η̂ _*_ | ξ̂ _1_ | ξ̂ _2_ | ξ̂ _*_
η̂ _1_ | 1 | 0.22 | 0.57 | 0.41 | 0.15 | 0.31
η̂ _2_ | | 1 | 0.89 | 0.23 | 0.46 [0.16]^*^ | 0.10
η̂ _*_ | | | 1 | 0.39 | 0.45 | 0.26
ξ̂ _1_ | | | | 1 | 0.74 | 0.93
ξ̂ _2_ | | | | | 1 | 0.79
ξ̂ _*_ | | | | | | 1

* 0.46 for the 11 paired studies; 0.16 for all 30 studies of shortened femur.

Note: Figure 2 shows scatterplots between η̂_1_, η̂_2_, ξ̂_1_ and ξ̂_2_.

Subscript 1 refers to shortened humerus and subscript 2 to shortened femur. Subscript ^*^ refers to JTPR or JFPR.

## Estimates of Diagnostic Accuracy

Table 8 shows the results of the meta-analyses. The upper part of the table (nonshaded rows a through f) shows results in the 11 paired studies. The lower part (shaded rows a through f) shows the corresponding results including the additional 19 studies on shortened femur. The table includes results from separate meta-analyses for each test using the normal approximation (row a) and the binomial likelihood (row b), and the following joint meta-analyses: using the normal approximation and accounting for within study correlation (row c); using the normal approximation and ignoring within-study correlation (i.e., setting the off-diagonal elements of Σ_k_ to zero; row d); using the multinomial likelihood (which models within study correlation; row e); and using independent binomials for each test in both diseased and nondiseased individuals (i.e., a discrete likelihood but ignoring the within-study correlations; row f).

Table 8 Point estimates and individual 95% confidence intervals with alternative meta-analysis methods

| Summary TPR (%) Short humerus | Summary TPR (%) Short femur | Summary JTPR (%) | Summary FPR (%) Short humerus | Summary FPR (%) Short femur | Summary JFPR (%)
Analyses in the 11 paired studies
Separate meta-analyses of the two tests
a. Bivariate, normal likelihood | 36.9 (29.3, 45.1) | 36.0 (26.0, 47.3) | NA | 5.0 (3.5, 7.1) | 7.6 (5.5, 10.3) | NA
b. Bivariate, binomial likelihood | 37.9 (27.7, 50.3) | 35.4 (23.1, 49.5) | NA | 4.8 (3.0, 7.4) | 7.4 (5.0, 10.7) | NA
Joint meta-analyses of the two tests
c. Normal likelihood, using within-study correlation | 37.3 (29.9, 45.5) | 37.5 (27.9, 48.1) | 30.9 (23.0, 40.2) | 4.9 (3.4, 7.0) | 7.6 (5.6, 10.2) | 3.0 (2.2, 4.1)
d. Normal likelihood, ignoring within-study correlation | 37.5 (29.4, 46.5) | 36.4 (26.1, 48.0) | 27.5 (19.5, 37.2) | 4.9 (3.4, 7.0) | 7.3 (5.3, 10.0) | 2.8 (2.0, 4.0)
e. Multinomial likelihood (uses within-study correlations) | 35.3 (26.9, 41.8) | 35.0 (22.4, 46.2) | 26.1 (16.6, 34.0) | 4.9 (2.8, 7.5) | 7.3 (4.6, 10.5) | 2.7 (1.6, 4.2)
f. Binomial likelihood (ignores within-study correlation) | 34.6 (20.3, 44.2) | 35.9 (20.5, 50.4) | 26.8 (11.3, 39.2) | 4.8 (2.9, 7.7) | 7.3 (4.6, 11.5) | 2.8 (1.7, 4.4)
Analyses in all 30 studies
Separate meta-analyses of the two tests
a. Bivariate, normal likelihood | 36.9 (29.3, 45.1) | 35.8 (29.1, 43.1) | NA | 5.0 (3.5, 7.1) | 7.6 (6.1, 9.4) | NA
b. Bivariate, binomial likelihood | 38.0 (27.8, 50.3) | 35.2 (27.8, 43.3) | NA | 4.8 (3.0, 7.4) | 7.4 (5.8, 9.3) | NA
Joint meta-analyses of the two tests
c. Normal likelihood, using within-study correlation | 34.2 (27.2, 42.0) | 37.1 (30.6, 44.2) | 29.8 (23.1, 37.5) | 4.9 (3.5, 6.7) | 7.6 (6.2, 9.4) | 3.0 (2.3, 3.8)
d. Normal likelihood, ignoring within-study correlation | 35.9 (28.9, 43.6) | 35.8 (29.0, 43.3) | 26.7 (20.4, 34.1) | 5.0 (3.6, 7.0) | 7.5 (6.1, 9.3) | 2.9 (2.2, 3.9)
e. Multinomial likelihood (uses within-study correlations) | 34.7 (27.9, 42.5) | 34.8 (28.7, 41.9) | 25.2 (18.9, 32.4) | 4.9 (3.1, 7.4) | 7.4 (6.0, 9.2) | 2.8 (1.9, 3.9)
f. Binomial likelihood (ignores within-study correlation) | 35.9 (27.7, 45.1) | 34.9 (28.0, 42.7) | 27.5 (19.2, 37.2) | 4.9 (3.1, 7.4) | 7.4 (5.8, 9.3) | 2.8 (1.8, 4.1)

FPR = false-positive rate (1−specificity); REML = restricted maximum likelihood; TPR = true-positive rate (sensitivity); JFPR/JTPR = joint-[false|true]-positive rate. The joint meta-analyses of the two tests use the unstructured variant of the between-study covariance matrix as per equation (24).

In general, the analyses give similar point estimates for the true-positive rates and similar point estimates for the false-positive rates. The 95% credible intervals in Bayesian models using discrete likelihoods (rows b, e, f) tend to be longer than the respective 95% confidence intervals in non-Bayesian models using the normal approximation. Overall, the lengths of the confidence or credible intervals in Table 8 differ only slightly between the separate and joint meta-analyses. To facilitate comparisons of the length of the confidence intervals between separate meta-analyses of each test and joint analyses, we report 95% confidence intervals that are not corrected for multiple comparisons. Specifically, we used z_0.025_ = 1.96 instead of q_α_ in (37), (38), (40), (41) and (42).

Including all 30 studies does not change the point estimates and confidence/credible intervals for shortened humerus appreciably. It results in lower uncertainty for shortened femur, as all 19 additional studies were on shortened femur.

Table 9 shows the standard errors and the standard deviations of the posteriors of the summary estimates in the logit scale for maximum likelihood and Bayesian analyses, respectively. Meta-analyses that model the within-study correlations between tests generally gives more precise estimates. Standard errors based on the Bayesian models with discrete likelihoods are larger than those from the non-Bayesian normal likelihoods. When all 30 studies are considered, differences in the standard errors or standard deviations between separate and joint meta-analyses are attenuated primarily for shortened femur, to which the additional data pertain.

Table 9 Standard errors or posterior standard deviations of logit-transformed summary effects with alternative meta-analysis methods

| SE/Posterior SD
| logit-TPR (shortened humerus) | logit-TPR (shortened femur) | logit-FPR (shortened humerus) | logit-FPR (shortened femur)
Analyses in the 11 paired studies
Separate meta-analyses of the two tests
a. Bivariate, normal likelihood | 0.1745 | 0.2397 | 0.1934 | 0.1714
b. Bivariate, binomial likelihood | 0.2430^*^ | 0.2957^*^ | 0.2399^*^ | 0.2072^*^
Joint meta-analyses of the two tests
c. Normal likelihood, using within-study correlation | 0.1715 | 0.2230 | 0.1947 | 0.1646
d. Normal likelihood, ignoring within-study correlation | 0.1871 | 0.2446 | 0.1910 | 0.1753
e. Multinomial likelihood (uses within-study correlations) | 0.1686^*^ | 0.2691^*^ | 0.2514^*^ | 0.2134^*^
f. Binomial likelihood (ignores within-study correlation) | 0.2581^*^ | 0.3405^*^ | 0.2659^*^ | 0.2456^*^
Analyses in all 30 studies
Separate meta-analyses of the two tests
a. Bivariate, normal likelihood | 0.1745 | 0.1560 | 0.1934 | 0.1173
b. Bivariate, binomial likelihood | 0.2423^*^ | 0.1730^*^ | 0.2397^*^ | 0.1306^*^
Joint meta-analyses of the two tests
c. Normal likelihood, using within-study correlation | 0.1692 | 0.1492 | 0.1720 | 0.1162
d. Normal likelihood, ignoring within-study correlation | 0.1646 | 0.1594 | 0.1764 | 0.1187
e. Multinomial likelihood (uses within-study correlations) | 0.1658^*^ | 0.1473^*^ | 0.2257^*^ | 0.1195^*^
f. Binomial likelihood (ignores within-study correlation) | 0.1919^*^ | 0.1651^*^ | 0.2308^*^ | 0.1257^*^

FPR = false-positive rate (1−specificity); SE = standard error; TPR = true-positive rate (sensitivity). The joint meta-analyses of the two tests use the unstructured variant of the between-study covariance matrix as per equation (24).

* Standard deviation of the posterior.

In sum, for estimating summaries of TPRs and FPRs, the payoff of joint meta-analyses versus separate meta-analyses is at best modest.

## Estimates of Comparative Diagnostic Accuracy

We can compare the TPRs and FPRs of shortened humerus and shortened femur using meta-analysis. A convenient metric is the difference between the summary TPRs or the summary FPRs of the tests. Another metric is the difference in the summary logit-TPRs (and the same for the logit-FPRs). The exponential of the latter is an odds ratio: it expresses how many times higher the odds of a true positive (or false positive) are when shortened humerus is the test, versus when shortened femur is the test. For both metrics, a positive difference in, e.g., the TPR favors shortened humerus, in that its average TPR is higher than that of shortened femur. A difference of zero favors neither test, and a negative difference favors shortened femur. For FPR the direction is reversed: a negative difference favors shortened humerus, and so on.

### Separate Meta-Analyses Versus Joint Analyses Accounting for Within-Study Correlations

Table 10 shows differences in the absolute scale, and Table 11 shows relative differences (differences in the logit scale and odds ratios). In each table, the point estimates are generally similar across analyses. This is congruent with Table 8, where the point estimates for the summary TPRs and FPRs were similar across analyses. However, the confidence or credible intervals are shorter for the joint meta-analyses compared with the corresponding separate meta-analyses. For example, consider the analyses using the discrete likelihood. Among the 11 paired studies, the length of the confidence interval for the difference in TPRs in row e (joint meta-analyses accounting for within-study correlations) is approximately half of that in row b (separate meta-analyses; Table 10). The corresponding confidence intervals for FPRs are approximately 20 percent shorter. It so happens that in analyses using binomial and multinomial likelihoods, the shortening of the credible intervals is more evident for the difference in TPRs and logit-TPRs. In analyses using the normal approximations, the gain (in terms of shortening confidence interval lengths) is maximal for the difference in FPRs and logit-FPRs.

Table 10 Comparative test performance: Differences in the summary TPRs or FPRs and corresponding standard errors or standard deviations of the posterior distributions

| Difference in TPR | post. SD_Diff_ or SE_Diff_ | Difference in FPR | post. SD_Diff_ or SE_Diff_
Analyses in the 11 paired studies
Separate meta-analyses of the two tests
a. Bivariate, normal likelihood | 0.9 (−12.5, 14.3) | 6.85 | −2.6 (−5.5, 0.4) | 1.51
b. Bivariate, binomial likelihood | 2.6 (−14.7, 19.8) | 8.70^*^ | −2.5 (−6.3, 1.1) | 1.83^*^
Joint meta-analyses of the two tests
c. Normal likelihood, using within-study correlation | −0.2 (−8.9, 8.6) | 4.45 | −2.8 (−4.7, −0.8) | 1.00
d. Normal likelihood, ignoring within-study correlation | 1.2 (−9.6, 12.0) | 5.51 | −2.4 (−4.4, −0.4) | 1.02
e. Multinomial likelihood (uses within-study correlations) | 0.0 (−8.9, 9.5) | 4.62^*^ | −2.5 (−5.4, 0.3) | 1.43^*^
f. Binomial likelihood (ignores within-study correlation) | −1.4 (−10.2, 8.8) | 4.81^*^ | −2.5 (−6.4, 0.5) | 1.68^*^
Analyses in all 30 studies
Separate meta-analyses of the two tests
a. Bivariate, normal likelihood | 1.0 (−9.6, 11.7) | 5.42 | −2.6 (−5.0, −0.2) | 1.24
b. Bivariate, binomial likelihood | 2.9 (−10.1, 17.0) | 6.87^*^ | −2.5 (−5.2, 0.5) | 1.44^*^
Joint meta-analyses of the two tests
c. Normal likelihood, using within-study correlation | −2.9 (−8.5, 2.7) | 2.86 | −2.7 (−4.6, −0.9) | 0.94
d. Normal likelihood, ignoring within-study correlation | 0.1 (−8.3, 8.4) | 4.26 | −2.5 (−4.2, −0.8) | 0.89
e. Multinomial likelihood (uses within-study correlations) | −0.2 (−8.9, 8.8) | 4.50^*^ | −2.5 (−4.9, 0.2) | 1.29^*^
f. Binomial likelihood (ignores within-study correlation) | 0.9 (−9.2, 11.6) | 5.29^*^ | −2.5 (−4.9, 0.2) | 1.30^*^

FPR = false-positive rate (1−specificity); SE = standard error; TPR = true-positive rate (sensitivity). The joint meta-analyses of the two tests use the unstructured variant of the between-study covariance matrix as per equation (24). For models fit with REML (rows a, c and d) the differences were calculated using the delta method on the fitted model parameters.

* Standard deviation of the posterior.

Bold italic font: Statistically significant difference (p<0.05) or posterior probability >0.975 that the difference is less than 0.

Table 11 Comparative test performance: Differences in the summary logit-TPRs or logit-FPRs and corresponding standard errors or standard deviations of the posterior distributions

Analysis | TPR | | | FPR
Analysis | Difference in logits | post. SD_Diff_ or SE_Diff_ | Odds ratio | Difference in logits | post. SD_Diff_ or SE_Diff_ | Odds ratio
Analyses in the 11 paired studies
Separate meta-analyses of the two tests
a. Bivariate, normal likelihood | 0.038 (−0.543, 0.619) | 0.2965 | 1.04 (0.58, 1.86) | −0.440 (−0.947, 0.066) | 0.2584 | 0.64 (0.39, 1.07)
b. Bivariate, binomial likelihood | 0.112 (−0.632, 0.889) | 0.3827^*^ | 1.12 (0.53, 2.43) | −0.452 (−1.086, 0.168) | 0.3166^*^ | 0.64 (0.34, 1.18)
Joint meta-analyses of the two tests
c. Normal likelihood, using within-study correlation | −0.006 (−0.309, 0.296) | 0.1544 | 0.99 (0.73, 1.34) | −0.480 (−0.810, −0.150) | 0.1684 | 0.62 (0.44, 0.86)
d. Normal likelihood, ignoring within-study correlation | 0.051 (−0.374, 0.476) | 0.2169 | 1.05 (0.69, 1.61) | −0.427 (−0.761, −0.093) | 0.1704 | 0.65 (0.47, 0.91)
e. Multinomial likelihood (uses within-study correlations) | 0.000 (−0.374, 0.447) | 0.2087^*^ | 1.00 (0.69, 1.56) | −0.443 (−0.956, 0.057) | 0.2533^*^ | 0.64 (0.38, 1.06)
f. Binomial likelihood (ignores within-study correlation) | −0.061 (−0.432, 0.408) | 0.2161^*^ | 0.94 (0.65, 1.50) | −0.444 (−1.058, 0.094) | 0.2807^*^ | 0.64 (0.35, 1.10)
Analyses in all 30 studies
Separate meta-analyses of the two tests
a. Bivariate, normal likelihood | 0.045 (−0.414, 0.504) | 0.2341 | 1.05 (0.66, 1.66) | −0.446 (−0.889, −0.003) | 0.2261 | 0.64 (0.41, 1.00)
b. Bivariate, binomial likelihood | 0.124 (−0.452, 0.724) | 0.2976^*^ | 1.13 (0.64, 2.06) | −0.451 (−1.006, 0.076) | 0.2730^*^ | 0.64 (0.37, 1.08)
Joint meta-analyses of the two tests
c. Normal likelihood, using within-study correlation | −0.127 (−0.316, 0.062) | 0.0965 | 0.88 (0.73, 1.06) | −0.474 (−0.810, −0.138) | 0.1733 | 0.62 (0.44, 0.87)
d. Normal likelihood, ignoring within-study correlation | 0.004 (−0.345, 0.354) | 0.1783 | 1.00 (0.71, 1.42) | −0.432 (−0.751, −0.112) | 0.1631 | 0.65 (0.47, 0.89)
e. Multinomial likelihood (uses within-study correlations) | −0.007 (−0.398, 0.385) | 0.1989^*^ | 0.99 (0.67, 1.47) | −0.446 (−0.939, 0.026) | 0.2415^*^ | 0.64 (0.39, 1.03)
f. Binomial likelihood (ignores within-study correlation) | 0.042 (−0.411, 0.505) | 0.2323^*^ | 1.04 (0.66, 1.66) | −0.444 (−0.953, 0.028) | 0.2468^*^ | 0.64 (0.39, 1.03)

FPR = false-positive rate (1−specificity); SE = standard error; TPR = true-positive rate (sensitivity). The joint meta-analyses of the two tests use the unstructured variant of the between-study covariance matrix as per equation (24).

* Standard deviation of the posterior.

Bold italic font: Statistically significant difference (p<0.05) or posterior probability >0.975 that the difference is less than 0.

The sensitivities do not differ beyond what is expected by chance. The corresponding odds ratios in are close to one, between 1.03 and 1.13. All analyses suggest that shortened femur has smaller summary false-positive rate than shortened humerus, corresponding to odds ratios of 0.64 or 0.65. The differences in the summary false-positive rates are statistically significant in the joint meta-analyses (albeit uncorrected for multiple comparisons).

### Separate Meta-Analyses Versus Joint Analyses Not Accounting for Within-Study Correlations

As shown in Table 10 and Table 11, there is gain in terms of shorter confidence or credible interval lengths from joint analyses compared with separate meta-analyses, even if the within-study correlations are ignored (assumed to be zero; compare rows a and d for analyses with normal approximations; and rows b and f for analyses using the discrete likelihood). However, the gain is less than that obtained when within-study correlations are accounted for.

Finally, when all 30 studies are included, the differences between separate meta-analyses, joint meta-analyses accounting for correlation and joint meta-analyses not accounting for correlation remain in the same direction, but are attenuated.

## Four-Dimensional 1.96-Standard-Error Volumes for Separate and Joint Meta-Analyses

In the example, accounting for within-study correlation has at best moderate impact on the length of the confidence intervals for meta-analysis means, but can result in tighter confidence intervals for differences of means (for assessing comparative test accuracy). These findings are not discordant. The explanation involves the concept of a “confidence volume,” which generalizes the confidence interval in more than one dimension. The same concept applies to credible intervals in Bayesian analyses in an analogous manner.

To introduce the concept, focus on the meta-analysis of the sensitivity and specificity of a single test, say shortened humerus. The bivariate meta-analysis model yields estimates of means of logit-transformed sensitivities and false-positive rates and their covariance. The geometric representation of the simultaneous confidence interval for the estimated means is a two-dimensional ellipse (Figure 3), whose shape is determined by the estimated covariance, and whose center is determined by the estimated means. The confidence intervals of the estimated means are projections of the elliptical contour corresponding to 1.96 standard errors (95% confidence ellipse). A fundamental metric is the area of the 95% confidence ellipse, in that it characterizes the distribution of the estimated means according to the model. The area can be calculated analytically (see Appendix).

Figure 3 1.96-standard-error confidence region (ellipse) for a bivariate meta-analysis of shortened humerus only

The area of the 1.96-standard-error region is 0.3496

FPR = false-positive rate (1-specificity); TPR = true-positive rate (sensitivity).

Note: The plot is on the logit scale. The black dot represents the summary point, i.e., the mean logit true-positive and false-positive rates for the 11 meta-analyzed studies of shortened humerus. The red horizontal lines represent the 95% confidence interval on the margin of the estimated mean logit true-positive rate, and the red vertical lines represent the corresponding 95% confidence intervals of the estimated mean logit false-positive rate. The ellipse is the 1.96-standard-error region of the joint distribution of the two estimated means.

Figure 3 contains an elliptical representation of the simultaneous confidence interval for the estimated means of the true-positive rate (TPR, or sensitivity) and false-positive rate (FPR, or one minus specificity) of the shortened humerus for detecting trisomy 21 for the 11 meta-analyzed studies, when TPR and FPR are analyzed jointly. The plot is on the logit scale. The area of the 95% confidence region is 0.3496. The coordinates of the summary point are −2.94 and −0.54. The graph also shows the projections of the ellipse on the vertical and horizontal axes, representing the 95% confidence interval on the margin of the estimated mean logit TPR and FPR, respectively. For logit TPR the confidence intervals range from −0.88 to −0.20, and for logit FPR they range from −3.32 to −2.56. The ellipse is the 1.96–standard-error region of the joint distribution of the two estimated means.

By contrast, separate univariate meta-analyses would effectively consider the estimated means as independent; the geometric representation of the estimated means with separate univariate meta-analyses is a rectangle (Figure 4). The 1.96-standard-error region of the rectangle is larger than that of the ellipse in Figure 3. (The type I error rate for the rectangle confidence region in Figure 4 is 1 − 0.95^2^ = 0.0975, so the rectangle does not have 95% coverage.) The coordinates of the summary point in Figure 4 come from separate meta-analyses, and are slightly different from Figure 3.

Figure 4 1.96-standard-error confidence region (rectangle) for independent meta-analyses of sensitivity and specificity (shortened humerus only)

The area of the 1.96-standard-error region is 0.5587

FPR = false-positive rate (1-specificity); TPR = true-positive rate (sensitivity).

Note: The plot is on the logit scale. The black dot represents the coordinates of the mean of logit-transformed sensitivity and false-positive rate for shortened humerus. The red horizontal lines represent the 95% confidence interval on the margin of the summary logit true-positive rate, and the red vertical lines represent the corresponding 95% confidence intervals of the summary logit false-positive rate. The rectangle is the 1.96-standard-error confidence region of the joint distribution of the two means, which have been obtained from separate univariate random effects meta-analyses with REML. The coordinates of the summary point in this figure come from separate meta-analyses, and are slightly different from Figure 3.

Figure 4 contains a rectangle that shows the 1.96–standard-error confidence region of the joint distribution of the means for the true-positive rate (TPR, or sensitivity) and false-positive rate (FPR, or one minus specificity) of the shortened humerus for detecting trisomy 21 for the 11 meta-analyzed studies when TPR and FPR are analyzed independently. The plot is on the logit scale. The coordinates of the summary point are −2.97 and −0.56. With separate meta-analyses the 1.96–standard-error confidence region is a rectangle, as the correlation between the logit TPR and logit FPR is explicitly ignored. The 95% confidence intervals for the mean logit TPR are −0.92 to −0.20 and for the sumary FPR are −3.36 to −2.58.

The concept of the confidence region extends to more dimensions. When one considers both tests, the summary logit sensitivities and false-positive rates have a joint distribution over four dimensions. Table 12 shows the calculated four-dimensional 1.96-standard-error confidence volumes for the alternative meta-analyses performed here. The confidence volume for joint meta-analyses is much smaller than that from separate meta-analyses for the two tests. The reason is that the joint analyses incorporate more information in the form of within-study correlations.

Table 12 Four-dimensional volumes within the 1.96-standard error hull for the summary estimates in alternative analyses (normal approximation modeling only)

| Volume (×10-3) | Ranking (small to large)
Analyses in the 11 paired studies
Separate meta-analyses of the two tests
a. Bivariate, normal likelihood | 13.4 | 3
b. Bivariate, binomial likelihood | Not calculated | –
Joint meta-analyses of the two tests
c. Normal likelihood, using within-study correlation | 4.9 | 1
d. Normal likelihood, ignoring within-study correlation | 12.0 | 2
e. Multinomial likelihood (uses within-study correlations) | Not calculated | –
f. Binomial likelihood (ignores within-study correlation) | Not calculated | –
Analyses in all 30 studies
Separate meta-analyses of the two tests
a. Bivariate, normal likelihood | 7.6 | 3
b. Bivariate, binomial likelihood | Not calculated | –
Joint meta-analyses of the two tests
c. Normal likelihood, using within-study correlation | 1.8 | 1
d. Normal likelihood, ignoring within-study correlation | 5.7 | 2
e. Multinomial likelihood (uses within-study correlations) | Not calculated | –
f. Binomial likelihood (ignores within-study correlation) | Not calculated | –

Note: The volumes do not have units and are on the logit scale. The joint meta-analyses of the two tests use the unstructured variant of the between-study covariance matrix as per equation (24).

When considering estimated means and the confidence intervals around them, we observe no great differences between separate meta-analyses of the two tests and joint analyses, in the same way as we see no great differences between the confidence intervals in Figure 3 and those in Figure 4. However, when we calculate differences of means we choose a projection that results in appreciable differences.

## Estimates of Between-Study Variance and Comparison of Structural Variants of T

Table 13 shows the estimated between-study variance from analyses using the normal approximation, and Table 14 shows posterior medians from analyses using discrete likelihoods. For ease of comparison, we have arranged results from separate meta-analyses in the same format as for results from joint meta-analyses.

Table 13 Estimates of between-study standard errors and correlations (analyses of the 11 paired studies)

Model | Normal approximation, estimates of τ′,R | Discrete likelihood, estimates of τ′,R
Separate meta-analyses | [ 0.448 0.696 - 0.590 0.536 - ] , [ 1 0 - 0.73 0 - 1 - 0 0.79 - - - - - 1 0 - 1 - - ] | [ 0.628 0.807 - 0.684 0.602 - ] , [ 1 0 - 0.53 0 - 1 - 0 0.64 - - - - - 1 0 - 1 - - ]
Joint meta-analyses (accounting for within-study correlation) | [ 0.446 0.637 0.578 0.609 0.520 0.513 ] , [ 1 0.69 0.90 0.66 0.34 0.61 1 0.92 0.41 0.79 0.69 1 0.48 0.56 0.62 1 0.57 0.90 1 0.88 1 ] | [ 0.432 0.717 0.612 0.739 0.611 0.630 ] , [ 1 0.74 0.84 0.88 0.78 0.94 1 0.97 0.40 0.90 0.73 1 0.54 0.85 0.78 1 0.48 0.88 1 0.82 1 ]
Joint meta-analyses (not accounting for within-study correlation) | [ 0.485 0.699 0.626 0.595 0.554 0.572 ] , [ 1 0.72 0.86 0.65 0.34 0.59 1 0.96 0.30 0.63 0.51 1 0.32 0.44 0.44 1 0.62 0.92 1 0.87 1 ] | [ 0.561 0.879 0.852 0.731 0.673 0.667 ] , [ 1 0.94 0.96 0.58 0.57 0.72 1 0.96 0.31 0.55 0.55 1 0.35 0.43 0.52 1 0.48 0.84 1 0.78 1 ]

Note: The table shows the factorization of the estimated covariance matrices into vectors of between-study standard deviations and correlation matrices, Note that T = diag(τ)R diag(τ), where diag(τ) is a matrix with the estimated standard deviations on the diagonal and with all off-diagonal elements 0, and R is a correlation matrix. The joint meta-analyses of the two tests use the unstructured variant of the between-study covariance matrix as per equation (24).

Table 14 Estimates of between-study standard errors and correlations (analyses of all 30 studies)

Model | Normal approximation, estimates of τ′,R | Discrete likelihood, estimates of τ′,R
Separate meta-analyses | [ 0.448 0.709 - 0.590 0.582 - ] , [ 1 0 - 0.73 0 - 1 - 0 0.28 - - - - - 1 0 - 1 - - ] | [ 0.627 0.793 - 0.683 0.639 - ] , [ 1 0 - 0.53 0 - 1 - 0 0.22 - - - - - 1 0 - 1 - - ]
Joint meta-analyses (accounting for within-study correlation) | [ 0.740 0.668 0.780 0.590 0.578 0.519 ] , [ 1 0.83 0.97 0.28 - 0.27 0.04 1 0.93 0.43 0.29 0.45 1 0.41 - 0.05 0.24 1 0.5 0.87 1 0.86 1 ] | [ 0.470 0.971 0.662 0.745 0.796 0.651 ] , [ 1 0.46 0.74 0.91 0.42 0.90 1 0.72 0.30 0.41 0.50 1 0.53 0.47 0.71 1 0.33 0.84 1 0.53 1 ]
Joint meta-analyses (not accounting for within-study correlation) | [ 0.475 0.721 0.592 0.628 0.592 0.603 ] , [ 1 0.78 0.89 0.41 0.07 0.31 1 0.98 0.08 0.27 0.21 1 0.22 0.24 0.28 1 0.67 0.93 1 0.89 1 ] | [ 0.575 1.149 0.765 0.751 0.833 0.703 ] , [ 1 0.52 0.90 0.71 0.37 0.77 1 0.64 0.19 0.30 0.39 1 0.43 0.31 0.57 1 0.36 0.83 1 0.52 1 ]

Note: The table shows the factorization of the estimated covariance matrices into vectors of between-study standard deviations and correlation matrices, Note that T = diag(τ)R diag(τ), where diag(τ) is a matrix with the estimated standard deviations on the diagonal and with all off-diagonal elements 0, and R is a correlation matrix. The joint meta-analyses of the two tests use the unstructured variant of the between-study covariance matrix as per equation (24).

All between-study correlations are almost always positive, and appear to be mostly congruent with each other. One should not overinterpret the differences in these estimates across models, because variance components are often not well estimated.