# Results

Our sample included 23 CERs. We identified published journal articles emerging from the review for 17 CERs. The full listing of CER report and journal article citations appears in Appendix A.

## Use

Table 2 provides a concise summary of the use of CER reports and journal articles by Dynamed, UpToDate and First Consult. A more detailed Evidence Table is provided in Appendix B. We identified citations (report or journal article citation) in one or more POC products for 13 of the 23 CER topics for which we searched for evidence summaries. Within CER topic, none of the CERs were used by all three POC tools. UpToDate used EPC CERs more often than DynaMed or FirstConsult. FirstConsult used the reviews the least. Many of the evidence summaries in FirstConsult had update dates before CER availability. Seven CER topics were cited by two POC tools. When two POC tools cited EPC CERs, it was most often DynaMed and UpToDate (5 CER topics), less often UpToDate and FirstConsult (2 CER topics). DynaMed and FirstConsult never both cited the same CER topic.

Table 2 Citation of EPC CERs in DynaMed, UpToDate, and FirstConsult

CER Topic, Year | Product | DynaMed | UpToDate | First Consult | Total POCs
Overactive Bladder in Women 2009^a^ | Report16 | | | | 0
Lipid-Modifying Agents 2009 | Report17 | | | | 0
Lipid-Modifying Agents 2009 | Journal article18 | ✓ | | | 1
Breast Lesion Diagnosis: Core Needle and Surgical Excision Biopsy 2009 | Report19 | | | | 0
Breast Lesion Diagnosis: Core Needle and Surgical Excision Biopsy 2009 | Journal article20 | | | | 0
Childhood Obesity Intervention Programs 2010 | Report21 | | | | 0
Childhood Obesity Intervention Programs 2010 | Journal article22 | | | | 0
Exercise-Induced Bronchoconstriction and Asthma 2010 | Report23 | | | | 0
Exercise-Induced Bronchoconstriction and Asthma 2010 | Journal article24-26 | | | | 0
Treatments for Rotator Cuff Tears 2010 | Report27 | ✓ | | | 1
Treatments for Rotator Cuff Tears 2010 | Journal article28 | ✓ | ✓ | | 2
Oral Diabetes Medications for Adults With Type 2 Diabetes-Update 2011 | Report29 | ✓ | | | 1
Oral Diabetes Medications for Adults With Type 2 Diabetes-Update 2011 | Journal article30, 31 | ✓ | ✓ | | 2
Drugs for Essential Hypertension-Update 2012 | Report32 | | | | 0
Drugs for Essential Hypertension-Update 2012 | Journal article33 | | | ✓ | 1
Management of Gastroesophageal Reflux Disease -update 2011 | Report34 | | ✓ | | 1
Analgesics for Osteoarthritis-update 2011 | Report35 | | | | 0
Diagnosis and Treatment of Clostridium difficile Infection 2011 | Report36 | | | | 0
Diagnosis and Treatment of Clostridium difficile Infection 2011 | Journal article37 | | ✓ | ✓ | 1
Second generation Antidepressants for Adult Depression 2011 | Report38 | | | | 0
Second generation Antidepressants for Adult Depression 2011 | Journal article39-42 | | ✓ | ✓ | 2
Antipsychotics in Children and Young Adults 2012^a^ | Report43 | | | | 0
Antipsychotics in Children and Young Adults 2012^a^ | Journal article44 | | | | 0
Treatments to Prevent Fractures in Low Bone Density-Update 2012 | Report | | ✓ | | 1
Drugs for Rheumatoid Arthritis 2012 | Report45 | | | | 0
Drugs for Psoriatic Arthritis (PA) 2012 | Report46 | | | | 0
Dietary Supplements in Adults Taking Cardiovascular Drugs 2012^a^ | Report47 | | | | 0
Dietary Supplements in Adults Taking Cardiovascular Drugs 2012^a^ | Journal article48 | | | | 0
Nonsurgical Treatments for Urinary Incontinence in Women 2012 | Report49 | | ✓ | | 1
Nonsurgical Treatments for Urinary Incontinence in Women 2012 | Journal article50-52 | ✓ | ✓ | | 2
Methods for Insulin Delivery and Glucose 2012 | Report53 | | | | 0
Methods for Insulin Delivery and Glucose 2012 | Journal article54, 55 | ✓ | ✓ | | 2
Screening and Diagnosis of Gestational Diabetes Mellitus 2012^b^ | Report56 | | ✓ | | 1
Screening and Diagnosis of Gestational Diabetes Mellitus 2012^b^ | Journal article57, 58 | | | | 0
Physical Therapy for Osteoarthritis-related Knee Pain 2012 | Report59 | | | | 0
Physical Therapy for Osteoarthritis-related Knee Pain 2012 | Journal article60 | | | | 0
Treatment for Restless Legs Syndrome 2012 | Report61 | | ✓ | | 1
Treatment for Restless Legs Syndrome 2012 | Journal article62 | | | | 0
Allergen-specific Immunotherapy: Rhinoconjunctivitis and/or Asthma 2013 | Report63 | | | | 0
Allergen-specific Immunotherapy: Rhinoconjunctivitis and/or Asthma 2013 | Journal article64, 65 | | | ✓ | 1
Total CER products cited | | 8 | 12 | 4
Total CER topics cited | | 6 (33%) | 10 (43%) | 4 (17%) | 13 (56%)
Reports cited | | 2 (9%) | 5 (22%) | 0 | 7 (30%)
CERs w/out journal articles | | 0 | 3 (50%) | 0 | 2 (33%)
CERs with journal articles | | 2 (12%) | 2 (12%) | 0 | 5 (29%)
Topics cited by at least one POC Tool | | | | | 9 (39%)

a We did not identify a relevant evidence summary topic in either POC tool.

b We did not identify specific summaries for Overactive Bladder; we therefore reviewed evidence summaries for Incontinence

Searching clinical POC tools for evidence summaries relevant to selected CERs was often straightforward (i.e., searching for evidence summaries relevant to the CER on second generation antidepressants for depression in adults identified evidence summaries titled “depression” and “antidepressant medication overview” as relevant). However, other CER topics did not always map as cleanly to POC evidence summaries (i.e., searching for evidence summaries relevant to the CER on dietary supplements in adults taking cardiovascular drugs identified vitamin supplementation for cardiovascular disease as one of the most relevant evidence summaries). In only one case, we could not identify an evidence summary we thought was relevant enough to warrant review. In another case, we searched for a specific condition that was addressed in a CER and the most relevant evidence summaries addressed broader topics (i.e., our search for evidence summaries addressing overactive bladder in women identified evidence summaries on the broader condition of urinary incontinence).

### Publication Type Used

Reports were cited by at least one POC tool for seven CER topics and journal articles were cited for nine. The publication type cited by at least one POC tool was the report in 30 percent and journal article in 39 percent of the CER topics we investigated. Both the report and the journal article were cited by at least one POC tool in 17 percent of the CER topics we investigated.

### DynaMed

All evidence summaries we reviewed had been updated since the relevant CER report was available. DynaMed cited a relevant CER for 5 of the 23 topics (26 percent). Only two reports were cited, one on oral diabetes medications and another on treatments for rotator cuff tears. The journal article was cited for 5 of the 17 topics with journal articles. Both times the report was cited, a journal articles was also cited for that topic. DynaMed evidence summaries did not cite any reports for which there was no journal article.

### UpToDate

All evidence summaries we reviewed in UpToDate had been recently updated according to the listed dates. These summaries cited EPC CERs for 10 of the 23 topics (43 percent). They cited reports for five topics, the journal article(s) for six topics, and both for one topic. Of the reports used by UpToDate, three related to CER topics without journal articles and two related to topics with journal articles.

### First Consult

First Consult was the only POC tool where the evidence summaries had not been updated recently. Nearly half (nine) of the evidence summaries we identified as relevant to the CER topic had not been updated since the AHRQ reports were posted. Only five of the updated and relevant evidence summaries cited four EPC CERs. Only journal articles (not full CER reports) were cited.

### Use by Publication Date

To enhance our understanding of the time lag between CER availability and use, we calculated use rates by CER publication year. This analysis appears in Table 3. In our convenience sample, we did not see trend in CER use by age of the CER. However, our small sample per year and CER selection criteria do not allow for meaningful interpretation of these data.

Table 3 CER use by publication year

Year | CERs Selected | Number of CERs (Reports and/or Journal Articles) Cited | Proportion Cited (report or journal article) by At Least One POC
2009 | 3 | 1 | 33%
2010 | 3 | 1 | 33%
2011 | 6 | 5 | 83%
2012 | 10 | 5 | 50%
2013 | 1 | 1 | 100%

## Consistency

Of the AHRQ CERs that were cited in POC tool evidence summaries, most were listed within the bibliography rather than in support of specific points. We did identify exceptions to this trend. Citations associated with specific content were identified for two CER topics in DynaMed. The Rotator Cuff Tear review was listed as general references and cited in a subsection about surgical techniques. The Methods for Insulin Delivery and Glucose Monitoring journal articles was also cited in reference to specific content in DynaMed's Insulin management evidence summary. The use of the information in these two citations was consistent with the AHRQ report findings.