# References

1 Agency for Healthcare Research and Quality. What is the effective health care program. 2013. http://www.effectivehealthcare.ahrq.gov/index.cfm/what-is-the-effective-health-care-program1/. August 28 2013.
2 Chambers D, Wilson PM, Thompson CA, et al. Maximizing the impact of systematic reviews in health care decision making: a systematic scoping review of knowledge-translation resources. Milbank Q. 89(1):131-56. [pmid: 21418315].
3 Viswanathan M, Nerz P, Dalberth B, et al. Assessing the Impact of AHRQ Evidence-based Practice Center (EPC) Reports on Future Research. Methods Future Research Needs Report No. 7. (Prepared by the RTI International–University of North Carolina Evidence-based Practice Center under Contract No. 290-2007-10056-I.) AHRQ Publication No. 11-EHC058-EF. Rockville, MD. Agency for Healthcare Research and Quality. 2011.
4 Personal communication from Portnoy, Allison- draft report titled ‘Opportunities for the Effective Health Care Program in Future Monitoring of Comparative Effectiveness Research (CER) Uptake and Utilization’. 2012.
5 Jones JB, Stewart WF, Darer JD, et al. Beyond the threshold: real-time use of evidence in practice. BMC Medical Informatics & Decision Making. 13:47. [pmid: 23587225].
6 Banzi R, Cinquini M, Liberati A, et al. Speed of updating online evidence based point of care summaries: prospective cohort analysis. BMJ. 2011;343:d5856. [pmid: 21948588].
7 Banzi R, Liberati A, Moschetti I, et al. A review of online evidence-based practice point-of-care information summary providers. J Med Internet Res. 2010;12(3):e26. [pmid: 20610379].
8 Prorok JC, Iserman EC, Wilczynski NL, et al. The quality, breadth, and timeliness of content updating vary substantially for 10 online medical texts: an analytic survey. J Clin Epidemiol. Dec. 2012;65(12):1289-95. [pmid: 22974495].
9 Addison J, Whitcombe J, William Glover S. How doctors make use of online, point-of-care clinical decision support systems: a case study of UpToDate. Health Info Libr J. 2013;30(1):13-22. [pmid: 23413790].
10 Ahmadi SF, Faghankhani M, Javanbakht A, et al. A comparison of answer retrieval through four evidence-based textbooks (ACP PIER, Essential Evidence Plus, First Consult, and UpToDate): a randomized controlled trial. Med Teach. 2011;33(9):724-30. [pmid: 21854150].
11 Duran-Nelson A, Gladding S, Beattie J, et al. Should we Google it? Resource use by internal medicine residents for point-of-care clinical decision making. Acad Med. 88(6):788-94. [pmid: 23619072].
12 Ketchum AM, Saleh AA, Jeong K. Type of evidence behind point-of-care clinical information products: a bibliometric analyis. J Med Internet Res. 13(1):e21. [pmid: 21335319].
13 Kronenfeld MR, Bay RC, Coombs W. Survey of user preferences from a comparative trial of UpToDate and ClinicalKey. J Med Libr Assoc. 2013;101(2):151-4. [pmid: 23646031].
14 Moja L, Banzi R, Tagliabue L. Review of “pull” point-of-care services. Int J Med Inform. Aug. 2011;80(8):604-5. [pmid: 21530382].
15 Sayyah Ensan L, Faghankhani M, Javanbakht A, et al. To compare PubMed Clinical Queries and UpToDate in teaching information mastery to clinical residents: a crossover randomized controlled trial. PLoS ONE. [Electronic Resource]. 2011;6(8):e23487. [pmid: 21858142].
16 Hartmann KE, McPheeters ML, Biller DH, et al. Treatment of overactive bladder in women. Evidence Report/Technology Assessment No. 187. (Prepared by the Vanderbilt Evidence-based Practice Center under Contract No. 290-2007-10065-I). AHRQ Publication No. 09-E017. Agency for Healthcare Research and Quality. Rockville, MD. August. 2009. http://www.effectivehealthcare.ahrq.gov/reports/final.cfm.
17 Sharma M, Ansari MT, Soares-Weiser K, et al. Comparative Effectiveness of Lipid-Modifying Agents. Comparative Effectiveness Review No. 16. (Prepared by the University of Ottawa Evidence-based Practice Center under contract No. 290-02-0021.). Agency for Healthcare Research and Quality. Rockville, MD. September. 2009. http://www.effectivehealthcare.ahrq.gov/reports/final.cfm.
18 Sharma M, Ansari MT, Abou-Setta AM, et al. Systematic review: comparative effectiveness and harms of combination therapy and monotherapy for dyslipidemia. Ann Intern Med. Nov. 3. 2009;151(9):622-30. [pmid: 19884623].
19 Bruening W, Schoelles K, Treadwell J, et al. Comparative Effectiveness of Core-Needle and Open Surgical Biopsy for the Diagnosis of Breast Lesions. Comparative Effectiveness Review No. 19. (Prepared by ECRI Institute Evidence-based Practice Center under Contract No. 290-02-0019.). Agency for Healthcare Research and Quality. Rockville, MD. December. 2009. http://www.effectivehealthcare.ahrq.gov/reports/final.cfm.
20 Bruening W, Fontanarosa J, Tipton K, et al. Systematic review: comparative effectiveness of core-needle and open surgical biopsy to diagnose breast lesions. Ann Intern Med. Feb. 16. 2010;152(4):238-46. [pmid: 20008742].
21 Whitlock EP, O'Conner EA, Williams SB, et al. Effectiveness of Primary Care Interventions for Weight Management in Children and Adolescents: An Updated, Targeted Systematic Review for the USPSTF. Evidence Synthesis No. 76. AHRQ Publication No. 10-05144-EF-1. Rockville MD. Agency for Healthcare Research and Quality. January. 2010. http://www.effectivehealthcare.ahrq.gov/reports/final.cfm.
22 Whitlock EP, O'Connor EA, Williams SB, et al. Effectiveness of weight management interventions in children: a targeted systematic review for the USPSTF. Pediatrics. Feb. 2010;125(2):e396-418. [pmid: 20083531].
23 Dryden DM, Spooner CH, Stickland MK, et al. Exercise-induced bronchoconstriction and asthma. Evidence Report/Technology Assessment No. 189. (Prepared by the University of Alberta Evidence-based Practice Center under Contract No. 290-2007-10021-I) AHRQ Publication No. 10-E001. Rockville, MD. Agency for Healthcare Research and Quality. 1530-4396 (Print) 1530-4396 (Linking). January. 2010. http://www.effectivehealthcare.ahrq.gov/reports/final.cfm.
24 Stickland MK, Rowe BH, Spooner CH, et al. Accuracy of eucapnic hyperpnea or mannitol to diagnose exercise-induced bronchoconstriction: a systematic review. Ann Allergy Asthma Immunol. 2011;107(3):229-34.e8. [pmid: 21875541].
25 Stickland MK, Rowe BH, Spooner CH, et al. Effect of warm-up exercise on exercise-induced bronchoconstriction. Med Sci Sports Exerc. 2012;44(3):383-91. [pmid: 21811185].
26 Stickland MK, Spooner CH, Dryden DM, et al. The need for standardization in exercise challenge testing for exercise-induced asthma/bronchoconstriction. J Allergy Clin Immunol. Oct. 2010;126(4):878-80 e6. [pmid: 20920779].
27 Seida JC, Schouten JR, Mousavi SS, et al. Comparative Effectiveness of Nonoperative and Operative Treatments for Rotator Cuff Tears. Comparative Effectiveness Review No. 22. (Prepared by the University of Alberta Evidence-based Practice Center under Contract No. 290-02-0023.) AHRQ Publication No. 10-EHC050. Rockville MD. Agency for Healthcare Research and Quality. July. 2010. www.effectivehealthcare.ahrq.gov/reports/final.cfm.
28 Seida JC, LeBlanc C, Schouten JR, et al. Systematic review: nonoperative and operative treatments for rotator cuff tears. Ann Intern Med. Aug. 17. 2010;153(4):246-55. [pmid: 20621893].
29 Bennett WL, Wilson LM, Bolen S, et al. Oral Diabetes Medications for Adults With Type 2 Diabetes: An Update. Comparative Effectiveness Review No. 27. (Prepared by Johns Hopkins University Evidence-based Practice Center under Contract No. 290-02-0018.) AHRQ Publication No. 11-EHC038-EF. Rockville, MD. Agency for Healthcare Research and Quality. March. 2011. www.effectivehealthcare.ahrq.gov/reports/final.cfm.
30 Bennett WL, Bass EB, Bolen S. Correction: Comparative effectiveness and safety of medications for type 2 diabetes. Ann Intern Med. Jul. 5. 2011;155(1):67-8. [pmid: 21858938].
31 Bennett WL, Maruthur NM, Singh S, et al. Comparative effectiveness and safety of medications for type 2 diabetes: an update including new drugs and 2-drug combinations. Ann Intern Med. May. 3. 2011;154(9):602-13. [pmid: 21403054].
32 Sanders GD, Coeytaux R, Dolor RJ, et al. Angiotensin-Converting Enzyme Inhibitors (ACEIs), Angiotensin II Receptor Antagonists (ARBs), and Direct Renin Inhibitors for Treating Essential Hypertension: An Update. Comparative Effectiveness Review No. 34. (Prepared by the Duke Evidence-based Practice Center under Contract No. 290-02-0025.) AHRQ Publication No. 11-EHC063-EF. Rockville MD. Agency for Healthcare Research and Quality. June. 2011.
33 Powers BJ, Coeytaux RR, Dolor RJ, et al. Updated report on comparative effectiveness of ACE inhibitors, ARBs, and direct renin inhibitors for patients with essential hypertension: much more data, little new information. J Gen Intern Med. Jun. 2012;27(6):716-29. [pmid: 22147122].
34 Ip S, Chung M, Moorthy D, et al. Comparative Effectiveness of Management Strategies for Gastroesophageal Reflux Disease: Update. Comparative Effectiveness Review No. 29. (Prepared by Tufts Medical Center Evidence-based Practice Center under Contract No. 290-2007-10055-I.) AHRQ Publication No. 11-EHC049-EF. 2011. Rockville MD. Agency for Healthcare Research and Quality. September. 2011.
35 Chou R, McDonagh MS, Nakamoto E, et al. Analgesics for Osteoarthritis: An Update of the 2006 Comparative Effectiveness Review. Comparative Effectiveness Review No. 38. (Prepared by the Oregon Evidence-based Practice Center under Contract No. 290-2007-10057 I) AHRQ Publication No. 11(12)-EHC076-EF. Rockville MD. Agency for Healthcare Research and Quality. October. 2011. http://www.ncbi.nlm.nih.gov/pubmed/22091473.
36 Butler M, Bliss D, Drekonja D, et al. Effectiveness of Early Diagnosis Prevention, and Treatment of Clostridium difficile Infection. Comparative Effectiveness Review No. 31. (Prepared by the Minnesota Evidence-based Practice Center under Contract No. 290-02-0009.) AHRQ Publication No. 11(12)-EHC051-EF. Rockville MD. Agency for Healthcare Research and Quality. December. 2011.
37 Drekonja DM, Butler M, MacDonald R, et al. Comparative effectiveness of Clostridium difficile treatments: a systematic review. Ann Intern Med. Dec. 20. 2011;155(12):839-47. [pmid: 22184691].
38 Gartlehner G, Hansen RA, Morgan LC, et al. Second-Generation Antidepressants in the Pharmacologic Treatment of Adult Depression: An Update of the 2007. Comparative Effectiveness Review. (Prepared by the RTI International–University of North Carolina Evidence-based Practice Center, Contract No. 290-2007-10056-I.) AHRQ Publication No. 12-EHC012-EF. Rockville, MD. Agency for Healthcare Research and Quality. Rockville MD:. December. 2011.
39 Gartlehner G, Gaynes BN, Hansen RA, et al. Comparative benefits and harms of second-generation antidepressants: background paper for the American College of Physicians. Ann Intern Med. Nov. 18. 2008;149(10):734-50. [pmid: 19017592].
40 Morgan L, Gartlehner G. Comparative efficacy, effectiveness and harms of second-generation antidepressants in the pharmacologic treatment of adult depression. European Psychiatry. 2011;26:1266.
41 Morgan L, Gartlehner G. Comparative benefits and harms of second-generation antidepressants in the pharmacologic treatment of depression in older adults and populations with comorbid conditions. European Psychiatry. 2012;27:1. [pmid: 22153731].
42 Thaler KJ, Morgan LC, Van Noord M, et al. Comparative effectiveness of second-generation antidepressants for accompanying anxiety, insomnia, and pain in depressed patients: a systematic review. Depress Anxiety. Jun. 2012;29(6):495-505. [pmid: 22553134].
43 Seida JC, Schouten JR, Mousavi SS, et al. First- and Second-Generation Antipsychotics for Children and Young Adults. Comparative Effectiveness Review No. 39. (Prepared by the University of Alberta Evidence-based Practice Center under Contract No. 290-2007-10021.) AHRQ Publication No. 11(12)-EHC077-EF. Rockville MD. Agency for Healthcare Research and Quality. 2012.
44 Seida JC, Schouten JR, Boylan K, et al. Antipsychotics for children and young adults: a comparative effectiveness review. Pediatrics. Mar. 2012;129(3):e771-84. [pmid: 22351885].
45 Donahue KE, Jonas DE, Hansen RA, et al. Drug Therapy for Rheumatoid Arthritis in Adults: An Update. Comparative Effectiveness Review No. 55. (Prepared by RTI-UNC Evidence-based Practice Center under Contract No. 290-02-0016-I). Rockville MD. Agency for Healthcare Research and Quality. April. 2012.
46 Donahue KE, Jonas D, Hansen RA, et al. Drug Therapy for Psoriatic Arthritis in Adults: Update of a 2007 Report. Comparative Effectiveness Review No. 54. (Prepared by RTI-UNC Evidence-based Practice Center under Contract No. 290-02-0016-I). Rockville MD. Agency for Healthcare Research and Quality. April. 2012. www.effectivehealthcare.ahrq.gov/reports/final.cfm.
47 Seely D, Kanji S, Yazdi F, et al. Dietary Supplements in Adults Taking Cardiovascular Drugs. Comparative Effectiveness Review No. 51. (Prepared by the University of Ottawa Evidence-based Practice Center under Contract No. 290-2007-10059-I). Rockville MD. Agency for Healthcare Research and Quality. April. 2012.
48 Kanji S, Seely D, Yazdi F, et al. Interactions of commonly used dietary supplements with cardiovascular drugs: a systematic review. Syst Rev. 2012;1:26. [pmid: 22651380].
49 Shamliyan T, Wyman J, Kane RL. Nonsurgical Treatments for Urinary Incontinence in Adult Women: Diagnosis and Comparative Effectiveness. Comparative Effectiveness Review No. 36. (Prepared by the University of Minnesota Evidence-based Practice Center under Contract No. 290-2007-10064-I). Rockville MD. Agency for Healthcare Research and Quality. April. 2012.
50 Shamliyan T, Wyman JF, Ramakrishnan R, et al. Benefits and harms of pharmacologic treatment for urinary incontinence in women: a systematic review. Ann Intern Med. Jun. 19. 2012;156(12):861-74. W301. 10. [pmid: 22711079].
51 Shamliyan TA, Kane RL, Wyman J, et al. Results availability from clinical research of female urinary incontinence. Neurourol Urodyn. Jan. 2012;31(1):22-9. [pmid: 22038753].
52 Talley KM, Wyman JF, Shamliyan TA. State of the science: conservative interventions for urinary incontinence in frail community-dwelling older adults. Nurs Outlook. Jul-Aug. 2011;59(4):215-20. 20 e1. [pmid: 21757078].
53 Golden SH, Brown T, Yeh HC, et al. Methods for Insulin Delivery and Glucose Monitoring: Comparative Effectiveness. Comparative Effectiveness Review No. 57. (Prepared by Johns Hopkins University Evidence-based Practice Center under Contract No. 290-2007-10061-I.) AHRQ Publication No. 12-EHC036-EF. Rockville MD. Agency for Healthcare Research and Quality. July. 2012.
54 Golden SH, Sapir T. Methods for insulin delivery and glucose monitoring in diabetes: summary of a comparative effectiveness review. J Manag Care Pharm. Aug. 2012;18(6 Suppl):S1-17. [pmid: 22984955].
55 Yeh HC, Brown TT, Maruthur N, et al. Comparative effectiveness and safety of methods of insulin delivery and glucose monitoring for diabetes mellitus: a systematic review and meta-analysis. Ann Intern Med. Sep. 4. 2012;157(5):336-47. [pmid: 22777524].
56 Hartling L, Dryden D, Guthrie A, et al. Screening and Diagnosing Gestational Diabetes Mellitus. Evidence Report/Technology Assessment No. 210. (Prepared by the University of Alberta Evidence-based Practice Center under Contract No. 290-2007-10021-I.) AHRQ Publication No. 12(13)-E021-EF. Rockville, MD. Agency for Healthcare Research and Quality. October. 2012.
57 Hartling L, Dryden DM, Guthrie A, et al. Benefits and Harms of Treating Gestational Diabetes Mellitus: A Systematic Review and Meta-analysis for the U.S. Preventive Services Task Force and the National Institutes of Health Office of Medical Applications of Research. Ann Intern Med. Jul. 16. 2013;159(2):123-9. [pmid: 23712381].
58 Donovan L, Hartling L, Muise M, et al. Screening tests for gestational diabetes: a systematic review for the u.s. Preventive services task force. Ann Intern Med. Jul. 16. 2013;159(2):115-22. [pmid: 23712349].
59 Shamliyan TA, Wang SY, Olson-Kellogg B, et al. Physical Therapy Interventions for Knee Pain Secondary to Osteoarthritis. Comparative Effectiveness Review No. 77. (Prepared by the Minnesota Evidence-based Practice Center under Contract No. 290-2007-10064-I.) AHRQ Publication No. 12(13)-EHC115-EF. Rockville, MD. Agency for Healthcare Research and Quality. November. 2012.
60 Wang SY, Olson-Kellogg B, Shamliyan TA, et al. Physical therapy interventions for knee pain secondary to osteoarthritis: a systematic review. Ann Intern Med. Nov. 6. 2012;157(9):632-44. [pmid: 23128863].
61 Wilt TJ, MacDonald R, Ouellette J, et al. Treatment for Restless Legs Syndrome. Comparative Effectiveness Review No. 86. (Prepared by the Minnesota Evidence-based Practice Center under Contract No. 290-2007-10064-I.) AHRQ Publication No. 12(13)-EHC147-EF. Rockville, MD. Agency for HealthcareResearch and Quality. 2012.
62 Wilt TJ, MacDonald R, Ouellette J, et al. Pharmacologic therapy for primary restless legs syndrome: a systematic review and meta-analysis. JAMA Intern Med. Apr. 8. 2013;173(7):496-505. [pmid: 23460396].
63 Lin SY, Erekosima N, Suarez-Cuervo C, et al. Allergen-Specific Immunotherapy for the Treatment of Allergic Rhinoconjunctivitis and/or Asthma: Comparative Effectiveness Review. Comparative Effectiveness Review No. 111. (Prepared by the Johns Hopkins University Evidence-based Practice Center under Contract No. 290-2007-10061-I.) AHRQ Publication No. 13-EHC061-EF. Rockville, MD. Agency for Healthcare Research and Quality. March. 2013.
64 Lin SY, Erekosima N, Kim JM, et al. Sublingual immunotherapy for the treatment of allergic rhinoconjunctivitis and asthma: a systematic review. JAMA. Mar. 27. 2013;309(12):1278-88. [pmid: 23532243].
65 Kim JM, Lin SY, Suarez-Cuervo C, et al. Allergen-specific immunotherapy for pediatric asthma and rhinoconjunctivitis: a systematic review. Pediatrics. Jun. 2013;131(6):1155-67. [pmid: 23650298].