# Methods

We selected a convenience sample of AHRQ EPC CER reports for which to track citations in POC tools. First, we included all CERs that were examined in the 2012 Web utilization project (n=13).4 We included these reports to compare use across resource type in a subsequent stage of this project. We next established criteria to select a second group of reports. Selection criteria were 1) report date between 2008 and 2012, 2) clinical topic commonly diagnosed and initially treated or referred from primary care. These report date criteria allowed time since the CER availability for the POC products to find the new information and update relevant evidence summaries. We narrowed the list of topics to those addressed in primary care because this audience appears to be the target of many clinical POC tools. We first applied these criteria to all Minnesota EPC reports that had not already been selected (n=3 met criteria). We focused on our EPC's reports because we were knowledgeable about these reports, had a database listing all associated journal articles, and had a vested interest in evaluating their utilization. We then applied the criteria to the population of CER reports conducted across all EPCs and selected those meeting the criteria (n=7) that were not already selected in a previous step. If two versions of a CER on the same topic appeared, we selected the most recent version. We arrived at a total sample of 23 reports.

Once we established the list of CERs, we compiled a list of published articles that emerged from those reviews. We used several methods to identify journal articles related to AHRQ reports. We conducted forward citation searching in Google Scholar to identify journal articles that cited the full report and searched for author names and titles consistent with the report. We also conducted MEDLINE searches for topic, dates, and author names consistent with the report.

Using this sample of reports and related articles, we conducted topic searches in three POC tools available through the University of Minnesota Libraries (DynaMed, UpToDate, and First Consult). We used search terms for the condition being addressed in the CER. When this search did not identify relevant evidence summaries, we searched using other relevant terms to identify any evidence summaries for which the CER would be relevant. We typically did not review evidence summaries on specific interventions, such as specific drugs or drug classes, unless a specific condition was not addressed in the CER. We reviewed the relevant evidence summaries provided in each POC tool to determine and document whether the CER report and/or journal article(s) were cited. We also noted the date that the POC evidence summary was updated to compare timing of the POC update relative to publication of the CER products.

We prepared tables documenting CER use across topic, POC tool, and publication year. Patterns of use are numerically summarized by CER and POC tool. We also include a narrative summary of findings within each product to provide more information than possible with numerical summaries.