# Discussion

We identified citations in one or more clinical POC tools for slightly more than half of the CERs we analyzed. Journal articles were used slightly more frequently that reports. Use of the CERs may be influenced by several factors, including POC evidence summary update timing, topic, POC tool, and accessibility of CER publication(s). UpToDate included more AHRQ CER product citations than DynaMed or First Consult. Evidence summaries in FirstConsult often lacked recent updates, making citation impossible. Citation of the CERs was typically to acknowledge reviews that had been conducted on the topic and not to make specific clinical points.

We hope to expand upon this pilot project and continue to collect and analyze data to identify patterns of use. Because use appears to be topic dependent, it was difficult with a small sample size to attempt to generate hypotheses about topic classification (general or specific, condition-focused vs. intervention focused, primary care vs. subspecialist, prevalence of condition, etc.), publication number and types, or publication timing on rate of use. Our results appeared to be a function of the convenience sample of reports we selected and our somewhat subjective selection criteria for what constituted a matching POC product. This could distort the findings, so our ability to analyze use patterns was limited. Additionally, simple numerical reporting and accounting may not be sufficient to fully understand use. Some CER topics better matched POC evidence summary topics, this is another pattern that could be explored in future research. We will gain more information to enhance the ability to identify trends as we expand data collection and analysis. We also expect that other factors we did not address might influence CER use. These include factors describing the topic nomination (guideline group vs. community member) or the degree of buy-in from experts in the field for CER topics (which could somehow be measured using a Technical Expert Panel and/or peer review recruitment information or acceptance of the findings based upon the peer reviews), the number of existing systematic reviews on the topic, etc. A more in-depth analysis specific to each POC tool might present useful information that could potentially influence uptake.

## Next Steps

This pilot project was conducted to provide quick information about the use of AHRQ EPC reports in clinician POC tools to determine whether more scientific and ongoing monitoring of these increasingly important clinician resources would be worthwhile. The information provided is interesting and valuable. However given the necessity of a quick turn-around, the methodology has significant limitations preventing more useful analysis and interpretation. We plan to enhance this pilot investigation to provide more in-depth, accurate, and meaningful analysis that will lead to generalizable conclusions. We specifically plan to address:

- [underlined: Selection of POC tools/enhanced background information.] We selected those available at the University of Minnesota. More in-depth investigation to the background, methodology, and aims of widely available POC tools would allow a more informed, contextualized, scientific (potentially), and appropriate-to-topic selection of tools. Additionally, an improved understanding of how the evidence summaries are created and updated within studied tools would provide valuable contextual information that may help to explain CER use.
- [underlined: Matching of CERs and POC tools.] Our pilot project selected a convenience sample of CERs and investigated their use in the most closely matched product within each POC tool. In some cases, the POC product did not exactly match the CER topic and this may have affected the rate of use. A larger sample may provide categorization of topics to calculate rates of use using more appropriate denominators. Another would be to identify as set of POC products for which a closely matched EPC CER was available and relevant to that evidence summary to assess use. This will be explored in future efforts.
- [underlined: Communication with POC tool vendors.] Our pilot project did not attempt to collect information from the creators or vendors of the POC tools. Our next phase of this project will begin with a more in-depth understanding of the POC tools and how they are used. We will also explore contacting the vendors of these tools for information or commentary considered important to understanding their use of our products.

## Conclusion

This pilot project represents an important first step in documenting use of EPC CERs in the increasingly popular clinical POC tools. We found evidence of moderate use of EPC CERs in three common POC products. Further research is necessary to identify patterns in these rates of use. POC tools are expected to become increasingly important resources for clinicians. Improved understanding of their use of EPC CERs could assist AHRQ in dissemination planning.