# Background

The Agency for Healthcare Research and Quality (AHRQ) established its Effective Health Care Program to help providers, patients, and other stakeholders make informed health care decisions about medical care. One of the primary ways they aim to accomplish this objective is through the funding of comparative effectiveness reviews (CERs).1 These systematic literature reviews compile data from completed clinical research to assess the evidence on specific medical interventions. Many CERs are conducted by Evidence-based Practice Centers (EPCs) which are funded though the Effective Health Care Program. EPCs conducting CERs submit comprehensive reports to AHRQ. These reports are posted for public review on the AHRQ Effective Health Care Web site. Condensed versions of the CERs are also typically published in one or more peer-reviewed journal articles that, in addition the reports, are meant to inform decision-making by providers, patients, and other stakeholders.

Evaluation of systematic review outputs and outcomes is necessary to ensure user needs are being met, demonstrate impact, plan future dissemination, and justify funding.2 While the EPC program has been in operation for some time, efforts to evaluate the use of our CERs are still being developed. One important ongoing activity is conducted by one of the AHRQ-funded EPCs, ECRI, which monitors and documents CER use as measured by citation in clinical practice guidelines. The RTI-UNC EPC conducted a special project to analyze the impact of two CERs, with emphasis on the creation of new research opportunities.3 AHRQ, with assistance from a student intern, completed a Web utilization project, based upon report hits and downloads, for a sample of CERs.4 Other efforts have assessed utilization by third party payers. None of the use monitoring activities or projects to date has addressed an increasingly popular type of resource for clinicians, clinical point-of-care (POC) tools.

Clinical POC tools (also called evidence-based textbooks, decision support aids, computerized decision-support systems, clinical reference tools, etc.) are electronic tools that clinicians can use anywhere and everywhere to find up to date summaries of research findings that can be applied in daily clinical practice. Several POC tools are available in the United States. Table 1 lists a few of the more popular POC tools. While some POC tools that interact with information in electronic health records to tailor information specifically to individual patient encounters have been developed5, our analysis focuses on the POC tools that provide general information not contextualized to the patient.

Table 1 Point-of-care tools: access and publisher

Point-of-Care Tool (Access) | Publisher
ACP Pier (open access to ACP members) | American College of Physicians (ACP)
BestBets (open access) | Department of Emergency Medicine, Manchester Royal Infirmary
Clinical Evidence (fee-based) | BMJ Publishing Group
DynaMed (fee-based) | EBSCO Publishing
eMedicine (open access) | WebMD-Medscape
EBM Guidelines (fee-based) | Wiley Blackwell Interscience and Duodecim
Essential Evidence Plus (fee-based) | Wiley Blackwell Interscience and Duodecim
First Consult (fee-based) | Elsevier
Micromedex (fee-based) | Thomson Reuters
UpToDate (fee-based) | UpToDate, Inc.

Note: Additional information about specific POC tools can be found at www.slideshare.net/ntorabi/point-of-care-tools-comparison-chart-2013.

These tools vary considerably in format, scope, content development methodology, quality, timing of information updates, and reporting format.6-8 Researchers at McMaster University evaluated 10 of these tools on three domains: quality (measured using a previously developed and validated scale), breadth of coverage, and timeliness of updates.8 They found DynaMed and UpToDate to have the best overall scores across the three domains. However, Clinical Evidence had the highest quality score, but was rated poorly for timeliness and breadth. UpToDate, DynaMed, and Micromedex tied for second in quality. UpToDate was ranked fifth for timeliness and first for breadth. This study limited selection of tools to those available at their library. Banzi, et al. conducted a comprehensive search to identify 18 point-of-care tools meeting specific inclusion criteria.7 They then assessed the POC tools on three domains: volume of medical conditions covered, editorial quality, and evidence-based methodology. Again, no POC tool was a clear frontrunner. Clinical Evidence, UpToDate, and eMedicine scored highest on editorial quality. BestBETs, Clinical Evidence, EBM Guidelines, and UpToDate scored the maximum number of point for evidence-based methodology. DynaMed, e-Medicine, First Consult scored highest on volume of topics covered. We did not review the literature on these tools systematically; however several other studies evaluating POC tools were identified.9-15

These tools are widely available and a frequently used resource by clinicians.8 Increasing use of these tools is likely as millennials (digital natives) continue to graduate to clinical positions and older clinicians (digital immigrants) leave the field, experience with electronic health records is gained, and POC tool industry marketing and product development grow in response to clinicians' need for easily accessible and digestible summarized evidence. This pilot study is a first step towards assessing whether AHRQ dissemination efforts reach POC evidence summary developers and therefore may be more likely to impact health care decisions through that channel.

To address the gap in current utilization monitoring activities, we conducted a pilot study to document and analyze the use of AHRQ CERs in three popular clinical POC tools: DynaMed, UpToDate, and First Consult. Specifically, we addressed the following Key Questions in this pilot project:

Key Question 1: Are EPC CERs used in clinician POC tools evidence summaries?

1a Which type(s) of EPC CER products are used?
1b Does time since review publication affect use?

Key Question 2: Is the information provided in select clinical POC evidence summaries consistent with relevant review findings?