# Relevant Point-of-Care Evidence Summaries

Table B1 Review of point-of-care tool evidence summaries for EPC CER citations