# CER Report and Journal Articles

Table A1 Comparative Effectiveness Reviews selected for utilization monitoring