# Results

## Searches of Published Literature

The initial and updated searches for published literature conducted in Medline, PubMed, Embase, and Cochrane Database of Systematic Reviews identified 1,738 citations. Figure 1 presents a Preferred Reporting Items for Systematic Reviews and Meta-Analyses (PRISMA) flow diagram of the study selection process. During title and abstract screening, 1,571 articles were excluded, and the remaining 154 articles were retrieved and evaluated at the full-text screening level. Of these, no articles were identified which addressed KQ1, and only four articles addressed KQ2. The four articles were eligible for abstraction, because they included at least one of the targeted disease/drug combinations, assessed QOL, and reported an association between PFS and QOL. Appendix G provides a list, by reason, of the 150 articles excluded during the full-text screening. After abstraction, all four studies remained eligible for quality review and data synthesis.

Figure 1 PRISMA flow diagram of study selection

KQ = Key Question

Figure 1 is a PRISMA diagram illustrating the review of articles identified via literature search for this methods paper. 1514 records were identified through the literature search. Of these 1510 were excluded at various stages of screening and 4 records were included.

## Searches of Gray Literature

The gray literature search yielded the following results:

- Regulatory Information: The search yielded a Food and Drug Administration (FDA) guidance document39 which provided background information on cancer endpoints, including detailed information on the use of PFS, but did not specifically elucidate relationships between PFS and other endpoints of interest to patients with cancer. Similar guidelines were identified in publications by the European Medicines Agency58 and Health Canada.59 In addition, four FDA new drug application briefing documents, two meeting transcripts, one approval package, one clinical review, an appeals document with review response, and 13 public presentations at workshops on endpoints were reviewed. Finally, nine European regulatory scientific summaries and seven Health Canada drug Summary Basis of Decisions were reviewed. None of these specifically addressed the relationship between PFS and other outcomes of importance to patients, therefore these documents provided only background information.
- Clinical trial registries: ClinicalTrials.gov was searched using combined search terms: “progression-free survival” AND “primary endpoint” AND “quality of life” and by combined search terms: “progression-free survival” AND “cancer” AND either “anxiety,” “depression” or “psychological.” Thirty-seven trials were identified, but review of the study descriptions revealed none that were relevant.
- The National Comprehensive Cancer Network (NCCN) oncology outcomes database and the ASCO (American Society of Clinical Oncology) annual meeting abstract database (past 3 years) were searched using the same terms as in the literature searches. Only one60 of 35 identified ASCO abstracts was relevant (an update of Zhou61), but no full-text article has been published. No relevant NCCN abstracts were identified.

## Key Questions

### KQ 1 When PFS is used as a primary clinical endpoint in treating patients with advanced cancers, is there direct evidence that knowing PFS impacts patient anxiety, depression, or psychological well-being? If yes, does the manner of communicating PFS affect patient anxiety, depression, or psychological well-being?

Based on the search criteria established for KQ1, we identified no studies that directly addressed the question. No information was obtained on patients’ psychological response to knowing their PFS status, or whether the manner of communicating PFS results affects patient anxiety or psychological well-being.

### KQ 2 For agents where PFS is the primary outcome measure being used to establish the performance (efficacy and safety) of a new drug, what evidence exists regarding the association of PFS with QOL or related outcomes, such as disease symptoms?

Four studies61–64 were identified that statistically evaluated the association between PFS and a QOL-related measure, with each study a post hoc analysis following a published primary study of drug efficacy and safety (see Study Design, Table 4). This pattern is the norm for QOL assessments, which are rarely reported at the time of the publication on primary treatment effect. Due to the post hoc analyses, these studies are at best viewed as exploratory, of use only in generating hypotheses for further study. Another concern given the delay in publishing QOL results is that there may be a time-lag bias occurring because of earlier publication of favorable results.65 These are important issues since high quality information on QOL is of great interest to patients who may wish to know whether they will observe a disease response while maintaining or improving daily function.

Table 4 Study characteristics

Author, Year | Cancer Type | Cancer Stage | Experimental Drug vs. Control | Study Design | 1° / 2° Outcomes | Total N (n Exp/Control) | Age, Mean (SD); Median (range)
Cella, 2012^62^ | Renal cell | Advanced, Stage IV, untreated or cytokine pretreated | pazopanib (Votrient) vs. placebo | Post hoc HRQL analysis of Sternberg 2010, phase III, randomized, double-blind, placebo-controlled, multicenter | PFS / OS, ORR, QOL, safety | 434 (289/145) ITT | pazopanib 59 (28–85); placebo 60 (25–81)
Sherrill, 2010^63^ | Breast | Metastatic, receptor-pos HER-2+, Stage IIIB/IIIC or IV, untreated | letrozole + lapatinib (Tykerb) vs. letrozole + placebo | Post hoc subset analysis (HER-2+ pts) of Johnston 2009, phase III, randomized, double-blind, placebo-controlled, parallel-group, multicenter | PFS / OS, ORR, QOL, clinical benefit rate | HER-2+ subset: 219 (111/108) | NR
Siena, 2007^64^ | Colorectal | Metastatic, progressed on prior Tx | panitumumab (Vectibix) + BSC vs. BSC alone | PFS-QOL association analysis of Van Cutsem 2007, phase III, randomized-controlled, open-label, multicenter | PFS / OS, ORR, QOL, safety | 463 (231/232) ITT | pan + BSC 62 (27–82); BSC alone 63 (27–83)
Zhou, 2009^61^ | Breast | Advanced, metastatic, HER2+, progressed on prior treatment | lapatinib (Tykerb) + capecitabine vs. capecitabine alone | HRQL analysis of Cameron 2008, phase III, randomized, open-label, multicenter | TTP / PFS, OS, ORR, QOL, clinical benefit rate, safety | 399 (198/201) ITT | lap+ cap 54 (26–80); cap alone 51 (28–83)

BSC = best supportive care; HER2 = human epidermal growth factor receptor type 2; HRQL = health-related quality of life; ITT = intention-to-treat; NSCLC = non–small-cell lung cancer; ORR = object response rate; OS = overall survival; PFS = progression-free survival; QOL = quality of life; TTP = time to progression

The study characteristics are presented in Table 4. Sample sizes ranged from 219 to 463. Overall, 1,515 patients were enrolled in these studies. The types of cancers and (treatment drug) included breast (Tykerb/lapatinib),61,63 colorectal (Vectibix/panitumumab),64 and renal cell (Votrient/pazopanib).62

The four drug studies all demonstrated statistically significant improvement in median PFS for the treatment arm compared with the control arm (Table 5). However, not surprisingly given the very different nature of the diseases and treatments studied, the range of times observed for PFS in the four reports varied markedly. In response to therapy, PFS showed increases in median duration from as low as 0.7 weeks (8 vs. 7.3 weeks;64 patients with end stage renal cancer being followed until death) to 5 months (9.2 vs. 4.2 months;63 patients with metastatic breast cancer who are expected to live an extended length of time even with disease recurrence.) These differences made it possible in the latter case to assess both the immediate and chronic toxicities associated with treatment, but this same evaluation was obviously not possible in the former. Because the nature of both disease and treatment vary greatly in the four examples studied, drawing conclusions from pooled outcomes is not feasible.

Table 5 Treatment efficacy and safety

Author, Year | Experimental Drug vs. Control | Median PFS (Experimental vs. Control) | PFS, Experimental vs. Control HR (95% CI) | Median OS (Experimental vs. Control) | OS, Experimental vs. Control HR (95% CI) | ORR, Experimental vs. Control % (95% CI) | Any Grade 3/4 Adverse Events in Experimental Group N (%) | Any Grade 3/4 Adverse Events in Control Group N (%)
Cella, 2012^62^ | pazopanib vs. placebo | 9.2 vs. 4.2 mos | 0.46 (0.34–0.62), p< 0.0001 | NR | NR (data not mature) | 30 vs. 3, p< 0.001 | 40% | 20%
Sherrill, 2010^63^ | letrozole + lapatinib vs. letrozole + placebo | 8.2 vs. 3 mos | 0.71 (0.53–0.96), p= 0.019 | 33.3 vs. 32.3 mos | 0.74 (0.5–1.1), p= 0.113 | 28 vs. 15, p= 0.021 | diarrhea 10%; rash 1% | diarrhea 1%; rash 0%
Siena, 2007^64^ | panitumumab + BSC vs. BSC alone | 8 wks vs. 7.3 (mean 13.8 wks vs. 8.5) | 0.54 (0.44–0.66), p<0.0001 | NR | 1.0 (82–1.22), p= 0.81 | 10 vs. 0 (at 1 yr) | of 229, 79 (35) | of 234, 45 (20)
Zhou, 2009^61^ | lapatinib + capecitabine vs. capecitabine alone | NR | 0.55 (0.4–0.74), p< 0.001 | 15.6 vs. 15.3 mos | 0.78 (0.55–1.12), p= 0.177 | 24 vs. 14, p= 0.017 | 35% | 33%

BSC = best supportive care; CI = confidence interval; HR = hazard ratio; Mo(s) = months; NR = not reported; ORR = objective response rate; P = probability; PFS = progression-free survival; OS = overall survival; Wks = weeks

The four studies all used validated assessment tools to collect QOL information (Table 6). They included at least one or more global QOL measures, such as the European Organization for Research and Treatment of Cancer – Quality of Life Questionnaire C-30, the functional assessment of cancer therapy: general, or the EuroQOL 5 dimensions index. Three of the studies also included disease-specific scales (the Functional Assessment of Cancer Therapy Colorectal Cancer symptom index)64 or subscales (the breast cancer subscale of the Functional Assessment of Cancer Therapy Breast)61,63 that addressed disease symptoms and/or general QOL measurement. All four studies established a minimally important difference threshold before analysis, but none provided detailed information on administration of the QOL measure (e.g., whether the QOL measure was administered in a standardized, reproducible manner each time, the conditions of administration, whether patients were informed of their PFS status prior to administration, etc.). QOL testing intervals ranged from 2- to 12-week intervals.

Table 6 QOL measurement description

Author, Year | QOL Measure | Significant Change Threshold | QOL Measure Administration | QOL Testing Intervals & Discontinuation Criteria | Timing of Drug Treatment | Variables Measured or Compared (Experimental vs. Control)
Cella, 2012^62^ | EORTC QLQ-C30, EQ-5D Index, EQ-5D VAS | QLQ-C30 5 to 10 pts; EQ-5D 0.08 pts; EQ-5D VAS 7 pts | blinded patient self-report | baseline, 6, 12, 18, 24, 48 weeks | daily until disease progression, unacceptable toxicity, death, or withdrawn consent | baseline scores; time to HRQL deterioration; correlation between response and HRQL
Sherrill, 2010^63^ | FACT-B total score, FACT-G, TOI | FACT-B 7–8 pts; BCS 2–3 pts; FACT-G/TOI 5–6 pts | self-administered | Day 1 (baseline), every 12 weeks, at study withdrawal | daily until disease progression or withdrawal from study due to toxicity or other reasons | baseline scores; change scores; correlation between QOL and tumor response
Siena, 2007^64^ | FACT-FCSI, EQ-5D Index, EQ-5D VAS, QLQ-C30 GHS | FCSI - 4-pt; EQ-5D - 0.08-pt.; EQ-5D VAS - 5.48-pt; GHS - 7.07-pt. | NR | baseline, every 2 weeks (FCSI) or monthly (all others) during treatment, at 30-day safety followup visit | 2-week cycles | association between mean changes in HRQL/disease symptoms and PFS
Zhou, 2009^61^ | FACT-B total score, FACT-G, TOI | FACT-B 7–8 pts; BCS 2–3 pts; FACT-G/TOI 5–6 pts | self-administered | at screening (baseline) visit, every 6 wks for 24 wks, every 12 wks, study discontinuation, until disease progression or withdrawal due to toxicity or other reasons | 21-day cycles until PD or withdrawal because of toxicity or other reasons | Baseline scores; change scores; QOL changes from baseline based on tumor response

BCM20 = Brain Cancer Module20; BSC = best supportive care; EORTC-QLQ = European Organization for Research and Treatment of Cancer Quality of Life Questionnaire; FACT-B = Functional Assessment of Cancer Therapy-Breast; FACT-G = FACT-general; FCSI = FACT Colorectal Symptom Index; GHS = Global Health Status; HRQL = health-related quality of life; PD = progressive disease; PF = physical functioning; PFS = progression-free survival; QOL = quality of life; TOI = Trial Outcome Index; VAS = Visual Analog Scale

A problem common to all four studies was significant patient dropout (Table 7). In two studies,63,64 the minimum requirement for inclusion in the analyses was QOL assessment at baseline and at least one followup. Even using this relatively liberal inclusion threshold, overall dropout rates ranged from 66 percent to 73 percent in experimental arms and from 77 percent to 96 percent in control arms. Disease progression was the major cause of dropout. All four studies addressed data missing not at random in the statistical plan.61–64 The most common technique used by these studies for addressing data missing not at random was last observation carried forward (LOCF).61,63,64 Of note, LOCF is not a recommended imputation method.66 The opportunity to follow patients for QOL or other PROs obviously varies depending on the course of patients with advanced disease. In patients with longer term survival (i.e., breast compared with renal cell cancer) it may be easier to collect data than in patients who are likely to progress and become symptomatic more quickly and to have shorter times until death. Regardless of the differences, missing data are always a challenge in the study of PROs, and this needs to be addressed in the research design.

Table 7 QOL Measurement—missing data

Author, Year | QOL Analysis- Requirement for Inclusion | Baseline Completion Rate N (%) (Exp/Ctrl) | Experimental Group Dropout N (%) | Control Group Dropout N (%) | Primary Reasons for Dropout | Statistical Method for Missing Data
Cella, 2012^62^ | All available HRQL assessments during periods of best response for each pt were used | QLQ-C30: 288 (99.7)/142 (97.9) EQ-5D: 287 (99.3)/143 (98.6) EQ-5D VAS: 283 (97.9)/141 (97) | wk 48, QLQ-C30 194 (67), EQ-5D 192 (67), EQ-5D VAS 188 (66) | wk 48, QLQ-C30 121 (85), EQ-5D 121 (85), EQ-5D VAS 118 (84) | disease progression | sensitivity analyses of HRQL deterioration using a composite end-point, where PD and HRQL deterioration were considered as an event
Sherrill, 2010^63^ | Baseline & at least one followup QOL assessment | 110 (100)/101 (98) | wk 48, 79 (72) | wk 48, 78 (77) | disease progression or withdrawal from Tx | LOCF - missing scores imputed from the last nonmissing score at a previous visit
Siena, 2007^64^ | Baseline & at least one followup QOL assessment | 207 (90)/184 (79) | wk 16, 145 (70) | wk 16, 177 (96) | disease progression | two methods, last value carried forward and slope method, used to impute missing values
Zhou, 2009^61^ | All data collected up to close of study enrollment (no data after crossover or alt tx) | 171 (86)/168 (84) | wk 24, 124 (73) | wk 24, 138 (82) | disease progression or withdrawal for other reasons | LOCF; exploratory random pattern effects model to deal with missing data showed QOL comparable bet Tx arms (data not shown)

BSC = best supportive care; HRQL = health-related quality of life; LOCF = last observation carried forward; NR = not reported; PD = progressive disease; PF = physical functioning; QOL = quality of life; QLQ = Quality of Life Questionnaire; VAS = Visual Analog Scale; Tx = treatment; Wk = week

The most important finding relating to this methods project was the relationship between PFS and QOL or other PRO, such as disease symptoms, found in all four studies (Table 8). More specifically, being progression-free had a statistically significant positive association with better QOL and/or decreased disease symptoms. All four studies demonstrated better QOL or disease symptoms among patients who remained progression-free compared with those who had progressed. Statistical methods to analyze the association between PFS and the QOL ranged from correlational techniques to more robust analysis of covariance (ANCOVA) and regression analyses. All four of the studies adjusted for QOL baseline scores in their analyses.

Table 8 PFS - QOL association

Author, Year | Cancer Type | Exp Drug vs. Control | PFS-QOL Association | PFS-QOL Statistical Method
Cella, 2012^62^ | Renal cell carcinoma | pazopanib vs. placebo | Progression-free (CR/PR) patients experienced significantly less HRQL deterioration than patients with SD and PD for GHS, EQ-5D utility index, EQ-5D VAS | Univariate and multivariate regression models, adjusted for baseline HRQL scores, were developed to determine the association between changes in HRQL and tumor response
Sherrill, 2010^63^ | Breast | letrozole + lapatinib vs. letrozole + placebo | At wks 24 and 36, average FACT-B change scores from baseline were statistically and clinically significantly improved for patients with no PD versus those with PD | Least squared means from an ANCOVA, adjusted for baseline value, was used to compared QOL score changes from baseline between progressors and nonprogressors
Siena, 2007^64^ | Colorectal | panitumumab + BSC vs. BSC alone | At week 8, being progression-free was associated with significantly and clinically meaningful lower CRC symptomatology for both treatment arms and higher HRQL for panitumumab patients only | T-tests and least-squares estimates were calculated for differences in QOL measures at weeks 4, 8, 12, 16 controlling for baseline score by progression status as of wk 8 (PD vs. no PD) within each treatment arm
Zhou, 2009^61^ | Breast | lapatinib + capecitabine vs. capecitabine alone | At 12 wks, patients with SD had significantly positive changes from baseline, whereas patients with PD had negative changes in FACT-B, FACT-G, TOI, EQ-5D utility index, EQ-5D VAS scores | ANCOVA examined the relationship between tumor response status (SD vs. PD) adjusted for baseline scores (treatment arms pooled for this analysis)

ANCOVA = analysis of covariance; BSC = best supportive care; CR = complete response; FACT-B = Functional Assessment of Cancer Therapy-Breast; FACT-G = Functional Assessment of Cancer Therapy-General; GHS = Global Health Status; HRQL = health-related quality of life; PD = progressive disease; PF = physical functioning; PR = partial response; QOL = quality of life; SD = stable disease; SF = social functioning; VAS = Visual Analog Scale

In the four included studies, there was better QOL or disease symptoms among patients who remained progression-free; however, the ability to draw conclusions from this important finding was compromised by the significant problems observed in the quality of these studies. As shown in Table 9, each of the four included studies met approximately 50 percent of identified quality items. However, all four failed to address the four items specifically developed to address the potential for bias in studies evaluating an association between PFS and QOL (items in italics). In addition, in all four studies there was substantial data missing not at random, and in two studies,55, 58 investigators and patients were not blinded to treatment. Missing data, censoring at progression, and overall lack of conformance with quality items were much more problematic than blinding in this methods paper. Based on the assessment of risk of bias and the overall study quality criteria (Table 3), all four studies received a poor quality rating.

Table 9 Summary of individual article quality assessments

Bias | Quality Criteria | Cella, 2012^62^ | Sherrill, 2010^63^ | Siena, 2007^64^ | Zhou, 2009^61^ | # of Studies Meeting Criterion
Selection Bias | Subjects in different groups recruited from same population | Yes | Yes | Yes | Yes | 4
Selection Bias | Subjects in different groups recruited over same time period | Yes | Yes | Yes | Yes | 4
Selection Bias | Inclusion/exclusion criteria clearly stated | Yes | Yes | Yes | Yes | 4
Selection Bias | Randomization used | Yes | Yes | Yes | Yes | 4
Selection Bias | Comparable baseline characteristics between groups | Yes | Yes | Yes | Yes | 4
Selection Bias | Apart from treatment under investigation, groups treated equally | Yes | Yes | Yes | Yes | 4
Selection Bias | Similarity between groups in potentially important confounders (e.g., those with and without PFS) or adequate adjustment for confounding * | No | No | No | No | 0
Selection Bias | Patients not censored at progression * | No | No | No | No | 0
Performance Bias | PFS assessed in valid and reliable manner (central radiology review, RECIST criteria used, inter- and intra-observer variability reported) | Yes | Yes | Yes | Yes | 4
Performance Bias | Subjects and investigators blind to treatment group | Yes | Yes | No | No | 2
Performance Bias | Subjects awareness of PFS status is described * | No | No | No | No | 0
Attrition Bias | Missing data addressed by description and analysis | Yes | Yes | Yes | Yes | 4
Attrition Bias | Results unlikely to be affected by losses to followup | No | No | No | No | 0
Attrition Bias | Missing data likely to be at random | No | No | No | No | 0
Detection Bias | Outcome (progression) assessors blind to treatment group | Yes | No | Yes | Yes | 3
Detection Bias | PFS and other endpoints defined | Yes | Yes | Yes | Yes | 4
Detection Bias | QOL administration process was described | No | No | No | No | 0
Detection Bias | A priori hypothesis regarding the relationship between PFS and QOL * | No | No | No | No | 0
# Yes (of 18 items) | | 12 | 11 | 11 | 11
Quality Assessment Rating (definitions in Table 3) | | Poor | Poor | Poor | Poor

PFS =progression-free survival; QOL = quality of life; RECIST = Response Evaluation Criteria in Solid Tumors

* Italicized criteria are those that are uniquely important to trials comparing PFS and QOL (see Appendix F)

The strength of evidence assessment goes beyond looking at study design alone, and takes into account other facets of the evidence, including the presence or absence of bias, directness, consistency, and precision.57 This allows clinicians, policy-makers, and patients to make well-informed decisions based on a more comprehensive evaluation of the evidence. Based on the poor quality of the four included articles, risk of bias was considered high. All four studies produced evidence of a positive association between PFS and QOL or disease symptoms, so although the body of evidence was small, it exhibited high consistency. However, this observation was tempered by the fact that the studies were of different designs, used different measurement tools, and assessed different outcomes. Consequently, it was not possible to measure the range of effect sizes. A quantitative analysis of pooled performance could not be performed, so no estimate of precision was possible. Based on the small body of literature identified and the factors discussed above, the strength of evidence is insufficient to demonstrate an association between PFS and QOL. Moreover, this association is only supportive of, but does not directly address KQ1, whether knowing PFS status impacts patient anxiety, depression, or psychological well-being, for which no direct evidence was found at all. Thus, the overall body of evidence is judged insufficient.