# References

1 Pazdur R. Endpoints for assessing drug activity in clinical trials. The Oncologist. 2008;13(Suppl 2):19-21. [pmid: 18434634].
2 Sridhara R, Johnson JR, Justice R, et al. Review of oncology and hematology drug product approvals at the U.S. Food and Drug Administration between July 2005 and December 2007. J Natl Cancer Inst. Feb. 24. 2010;102(4):230-43. [pmid: 20118413].
3 Dancey JE, Dodd LE, Ford R, et al. Recommendations for the assessment of progression in randomised cancer treatment trials. Eur J Cancer. Jan. 2009;45(2):281-9. [pmid: 19097775].
4 Hotte S, Bjarnason G, Heng D, et al. Progression-free survival as a clinical trial endpoint in advanced renal cell carcinoma. Curr Oncol. 2011;18(Suppl 2):S11-S9. [pmid: 21969807].
5 Biomarkers and surrogate endpoints: Preferred definitions and conceptual framework (Biomarkers Definitions Working Group). Clin Pharmacol Ther. 2001;69(3):89-95. [pmid: 11240971].
6 Shi Q, Sargent DJ. Meta-analysis for the evaluation of surrogate endpoints in cancer clinical trials. Int J Clin Oncol. Apr. 2009;14(2):102-11. [pmid: 19390940].
7 Prentice RL. Surrogate endpoints in clinical trials: Definition and operational criteria. Stat Med. 1989;8(4):431-40. [pmid: 2727467].
8 Buyse M, Molenberghs G. Criteria for the validation of surrogate endpoints in randomized experiments. Biometrics. 1998;54(3):1014-29. [pmid: 9840970].
9 Freedman L, Graubard B. Statistical validation of intermediate endpoints for chronic diseases. Stat Med. 1992;11(2):167-78. [pmid: 1579756].
10 Broglio KR, Berry DA. Detecting an overall survival benefit that is derived from progression-free survival. J Natl Cancer Inst. Dec. 2. 2009;101(23):1642-9. [pmid: 19903805].
11 Amir E, Seruga B, Kwong R, et al. Poor correlation between progression-free and overall survival in modern clinical trials: Are composite endpoints the answer?. Eur J Cancer. 2012;48(3):385-8. [pmid: 22115991].
12 Buyse M. Use of meta-analysis for the validation of surrogate endpoints and biomarkers in cancer trials. Cancer J. 2009;15(5):421-5. [pmid: 19826362].
13 Buyse M, Burzykowski T, Carroll K, et al. Progression-free survival is a surrogate for survival in advanced colorectal cancer. J Clin Oncol. Nov. 20. 2007;25(33):5218-24. [pmid: 18024867].
14 Saad ED, Katz A, Hoff PM, et al. Progression-free survival as surrogate and as true end point: insights from the breast and colorectal cancer literature. Ann Oncol. Jan. 2010;21(1):7-12. [pmid: 19901012].
15 Tang P, Bentzen S, Chen E, et al. Surrogate end points for median overall survival in metastatic colorectal cancer: Literature-based analysis from 39 randomized controlled trials of first-line chemotherapy. J Clin Oncol. 2007;25(29):4562-8. [pmid: 17876010].
16 Gill S, Berry S, Biagi J, et al. Progression-free survival as a primary endpoint in clinical trials of metastatic colorectal cancer. Curr Oncol. 2011;18(Suppl 2):S5-S10. [pmid: 21969810].
17 Yothers G. Toward progression-free survival as a primary end point in advanced colorectal cancer. J Clin Oncol. Nov. 20. 2007;25(33):5153-4. [pmid: 18024861].
18 Bast RC, Thigpen JT, Arbuck SG, et al. Clinical trial endpoints in ovarian cancer: report of an FDA/ASCO/AACR Public Workshop. Gynecol Oncol. Nov. 2007;107(2):173-6. [pmid: 17950384].
19 Markman M. Why overall survival should not be the sole valid primary endpoint of phase 3 ovarian cancer chemotherapy trials. Gynecol Oncol. Aug. 2007;106(2):279-81. [pmid: 17662376].
20 Oza A, Castonguay V, Tsoref D, et al. Progression-free survival in advanced ovarian cancer: a Canadian review and expert panel perspective. Curr Oncol. 2011;18(Suppl 2):S20-7. [pmid: 21969808].
21 Burzykowski T, Buyse M, Piccart-Gebhart MJ, et al. Evaluation of tumor response, disease control, progression-free survival, and time to progression as potential surrogate end points in metastatic breast cancer. J Clin Oncol. April. 20. 2008. 2008;26(12):1987-92. [pmid: 18421050].
22 Bergmann L, Hirschfeld S, Morris C, et al. Progression-free survival as an end-point in clinical trials of biotherapeutic agents. Eur J Cancer Suppl. 2007;5(9):23-8.
23 Fleming TR, Rothmann MD, Lu HL. Issues in using progression-free survival when evaluating oncology products. J Clin Oncol. Jun. 10. 2009;27(17):2874-80. [pmid: 19414672].
24 Stone AM, Bushnell W, Denne J, et al. Research outcomes and recommendations for the assessment of progression in cancer clinical trials from a PhRMA working group. Eur J Cancer. Aug. 2011;47(12):1763-71. [pmid: 21435858].
25 Zhuang S, Xiu L, Elsayed Y. Overall survival: A gold standard in search of a surrogate: The value of progression-free survival and time to progression as end points of drug efficacy. Cancer J. 2009;15(5):395-400. [pmid: 19826359].
26 Panageas KS, Ben-Porat L, Dickler MN, et al. When you look matters: the effect of assessment schedule on progression-free survival. J Natl Cancer Inst. Mar. 21. 2007;99(6):428-32. [pmid: 17374832].
27 Freidlin B, Korn EL, Hunsberger S, et al. Proposal for the use of progression-free survival in unblinded randomized trials. J Clin Oncol. May. 20. 2007;25(15):2122-6. [pmid: 17513819].
28 Bhattacharya S, Fyfe G, Gray RJ, et al. Role of sensitivity analyses in assessing progression-free survival in late-stage oncology trials. J Clin Oncol. Dec. 10. 2009;27(35):5958-64. [pmid: 19826121].
29 Amit O, Bushnell W, Dodd L. Blinded central review of the progression-free survival endpoint. Oncologist. 2010;15(5):492-5. [pmid: 20489186].
30 Dodd LE, Korn EL, Freidlin B, et al. Blinded independent central review of progression-free survival in phase III clinical trials: important design element or unnecessary expense?. J Clin Oncol. Aug. 1. 2008;26(22):3791-6. [pmid: 18669467].
31 Ford R, Schwartz L, Dancey J, et al. Lessons learned from independent central review. Eur J Cancer. Jan. 2009;45(2):268-74. [pmid: 19101138].
32 Pignatti F, Hemmings R, Jonsson B. Is it time to abandon complete blinded independent central radiological evaluation of progression in registration trials?. Eur J Cancer. Aug. 2011;47(12):1759-62. [pmid: 21641204].
33 Tang PA, Pond GR, Chen EX. Influence of an independent review committee on assessment of response rate and progression-free survival in phase III clinical trials. Ann Oncol. Jan. 2010;21(1):19-26. [pmid: 19875758].
34 Amit O, Mannino F, Stone AM, et al. Blinded independent central review of progression in cancer clinical trials: results from a meta-analysis. Eur J Cancer. Aug. 2011;47(12):1772-8. [pmid: 21429737].
35 Oxnard GR, Zhao B, Sima CS, et al. Variability of lung tumor measurements on repeat computed tomography scans taken within 15 minutes. J Clin Oncol. Aug. 10. 2011;29(23):3114-9. [pmid: 21730273].
36 Axelrod RC. The significance of progression-free survival as a clinical endpoint in oncology. Drug Benefit Trends. 2010;22(2):39-45.
37 Fallowfield LJ, Fleissig A. The value of progression-free survival to patients with advanced-stage cancer. Nat Rev Clin Oncol. 2011;9(1):41-7. [pmid: 22009075].
38 Cleeland C, Sloan J, Cella D, et al. Recommendations for including multiple symptoms as endpoints in cancer clinical trials : A report from the ASCPRO (Assessing the Symptoms of Cancer Using Patient-Reported Outcomes) Multisymptom Task Force. Cancer. Jan. 15. 2013;119(2):411-20. [pmid: 22930243].
39 U.S. Food and Drug Administration. Guidance for Industry: Clinical Trial Endpoints for the Approval of Cancer Drugs and Biologics. May. 2007.
40 Mohamed AF, Hauber AB, Neary MP. Patient benefit-risk preferences for targeted agents in the treatment of renal cell carcinoma. Pharmacoeconomics. 2011;29(11):977-88. [pmid: 21854079].
41 Bridges JF, Mohamed AF, Finnern HW, et al. Patients’ preferences for treatment outcomes for advanced non-small cell lung cancer: A conjoint analysis. Lung Cancer. Jul. 2012;77(1):224-31. [pmid: 22369719].
42 Hartzband P, Groopman J. There is more to life than death. N Engl J Med. 2012;367(11):987-9. [pmid: 22970943].
43 Johnson JR. End points and United States Food and Drug Administration approval of oncology drugs. J Clin Oncol. 2003;21(7):1404-11. [pmid: 12663734].
44 Dagher R, Johnson J, Williams G, et al. Accelerated approval of oncology products: A decade of experience. J Natl Cancer Inst. 2004;96(20):1500-9. [pmid: 15494600].
45 U.S. Food and Drug Administration. Guidance for industry: patient-reported outcome measures: use in medical product development to support labeling claims: draft guidance. Health Qual Life Outcomes. 2006;4:79. [pmid: 17034633].
46 Juni P, Holenstein F, Sterne J, et al. Direction and impact of language bias in meta-analyses of controlled trials: empirical study. Int J Epidemiol. Feb. 2002;31(1):115-23. [pmid: 11914306].
47 Moher D, Pham B, Klassen TP, et al. What contributions do languages other than English make on the results of meta-analyses?. J Clin Epidemiol. Sep. 2000;53(9):964-72. [pmid: 11004423].
48 Supplement 2. Use of Directed Acyclic Graphs (DAGs). Developing a Protocol for Observational Comparative Effectiveness Research (OCER): A User’s Guide. (Draft AHRQ Publication posted in May 2012). Rockville, MD. Agency for Healthcare Research and Quality. www.effectivehealthcare.ahrq.gov/ehc/products/440/1067/AHRQ_CER_Protocol_User_s_Guide_DRAFT-COPY_AllChapters.pdf. Accessed May 24, 2012.
49 Turner R, Spiegelhalter D, Smith G, et al. Bias modelling in evidence synthesis. J R Stat Soc. 2009;172(1):21-47. [pmid: 19381328].
50 Deeks JJ, Dinnes J, D’Amico R, et al. Evaluating nonrandomized intervention studies. Health Technol Assess. 2003;7(27):1-173. [pmid: 14499048].
51 Higgins JPT, Green S. The Cochrane handbook for systematic reviews of interventions. Cochrane Handbook. Chichester, West Sussex, UK. John Wiley & Sons, Ltd. 2005;3.
52 Downs SH, Black N. The feasibility of creating a checklist for the assessment of the methodological quality borth of randomised and nonrandomised studies of health care interventions. J Epidemiol Community Health. 1998;52(6):377-84. [pmid: 9764259].
53 Viswanathan M, Ansari MT, Berkman ND, et al. Assessing the Risk of Bias of Individual Studies in Systematic Reviews of Health Care Interventions. Methods Guide for Comparative Effectiveness Reviews. AHRQ Publication No. 12-EHC047-EF. Rockville, MD. Agency for Healthcare Research and Quality. March. 2012.
54 Hao Y. Patient-reported outcomes in support of oncology product labeling claims: regulatory context and challenges. Expert Rev Pharmacoecon Outcomes Res. 2010;10(4):407-20. [pmid: 20715918].
55 Meyer KB, Clayton KA. Measurement and analysis of patient-reported outcomes. Methods Mol Biol. 2009;473:155-69. [pmid: 19160737].
56 Wood AM, White IR, Thompson SG. Are missing outcome data adequately handled? A review of published randomized controlled trials in major medical journals. Clin Trials. 2004;1(4):368-76. [pmid: 16279275].
57 Owens DK, Lohr KN, Atkins D, et al. AHRQ Series Paper 5: Grading the strength of evidence when comparing medical interventions. Agency for Healthcare Research and Quality and the Effective Healthcare Program J Clin Epidemiol. 2010;63(5):513-23. [pmid: 19595577].
58 European Medicines Agency. Methodological considerations for using progression-free survival (PFS) as a primary endpoint in confirmatory trials for registration. EMEA. London. January. 2008.
59 Health Canada. Issue Analysis Summary: The use of progression-free survival as the efficacy endpoint for approval of targeted and chemotherapeutic agents for advanced cancer. August. 2007.
60 Zhou C, Wu YL, Chen G, et al. Updated efficacy and quality-of-life (QoL) analyses in OPTIMAL, a phase III, randomized, open-label study of first-line erlotinib versus gemcitabine/carboplatin in patients with EGFR-activating mutation-positive (EGFR Act Mut+) advanced non-small cell lung cancer (NSCLC). ASCO Meeting Abstracts. 2011 June 9. 2011;29(15, suppl):7520.
61 Zhou X, Cella D, Cameron D, et al. Lapatinib plus capecitabine versus capecitabine alone for HER2+ (ErbB2+) metastatic breast cancer: quality-of-life assessment. Breast Cancer Res Treat. 2009;117(3):577-89. [pmid: 19153829].
62 Cella D, Pickard AS, Duh MS, et al. Health-related quality of life in patients with advanced renal cell carcinoma receiving pazopanib or placebo in a randomised phase III trial. Eur J Cancer. 2012;48(3):311-23. [pmid: 21689927].
63 Sherrill B, Amonkar MM, Sherif B, et al. Quality of life in hormone receptor–positive HER-2+ metastatic breast cancer patients during treatment with letrozole alone or in combination with lapatinib. Oncologist. September. 1. 2010. 2010;15(9):944-53. [pmid: 20798196].
64 Siena S, Peeters M, Van Cutsem E, et al. Association of progression-free survival with patient-reported outcomes and survival: results from a randomised phase 3 trial of panitumumab. Br J Cancer. 2007;97(11):1469-74. [pmid: 18040272].
65 Hopewell S, Clarke M, Stewart L, et al. Time to publication for results of clinical trials. Cochrane Database Syst Rev. 2007;18(2). [pmid: 17443632].
66 Little R, D’Agostino R, Cohen M, et al. The prevention and treatment of missing data in clinical trials. N Engl J Med. 2012;367(14):1355-60. [pmid: 23034025].
67 Lipscomb J, Gotay CC, Snyder C. Patient-reported outcomes in cancer: A review of recent research and policy initiatives. CA Cancer J Clin. 2007;57(5):278-300. [pmid: 17855485].
68 Basch E. The missing voice of patients in drug-safety reporting. N Engl J Med. 2010;362(10):865-9. [pmid: 20220181].
69 Lheureux M, Raherison C, Vernejoux JM, et al. Quality of life in lung cancer: Does disclosure of the diagnosis have an impact?. Lung Cancer. 2004;43(2):175-82. [pmid: 14739038].
70 Otani H, Morita T, Esaki T, et al. Burden on oncologists when communicating the discontinuation of anticancer treatment. Jpn J Clin Oncol. 2011;41(8):999-1006. [pmid: 21764830].
71 Shaw J, Dunn S, Heinrich P. Managing the delivery of bad news: An in-depth analysis of doctors’ delivery style. Patient Educ Counsel. May. 2012;87(2):186-92. [pmid: 21917397].
72 Beaumont JL, Butt Z, Baladi J, et al. Patient-reported outcomes in a phase III study of everolimus versus placebo in patients with metastatic carcinoma of the kidney that has progressed on vascular endothelial growth factor receptor tyrosine kinase inhibitor therapy. Oncologist. 2011;16(5):632-40. [pmid: 21459902].
73 Carey MS, Bacon M, Tu D, et al. The prognostic effects of performance status and quality of life scores on progression-free survival and overall survival in advanced ovarian cancer. Gynecol Oncol. 2008;108(1):100-5. [pmid: 17920108].
74 Cella D, Bushmakin AG, Cappelleri JC, et al. Baseline quality of life as a prognostic survival tool in patients receiving sunitinib for metastatic renal cell carcinoma. Br J Cancer. 2012;106(4):646-50. [pmid: 22240794].
75 Cella D, Cappelleri JC, Bushmakin A, et al. Quality of life predicts progression-free survival in patients with metastatic renal cell carcinoma treated with sunitinib versus interferon alpha. J Oncol Pract. 2009;5(2):66-70. [pmid: 20856722].
76 Rubin DB. On the limitations of comparative effectiveness research. Stat Med. 2010;29(19):1991-5. [pmid: 20683890].
77 Wilkerson J, Fojo T. Progression-free survival is simply a measure of a drug’s effect while administered and is not a surrogate for overall survival. Cancer J. 2009;15(5):379-85. [pmid: 19826357].