# Methods

The Methods chapter describes the purpose and composition of the Technical Expert Panel (TEP), the Key Question (KQ) development and rationale, eligibility criteria, the search strategies used for published and gray literature, and the processes for article screening and selection, data abstraction, quality assessment, and data synthesis.

## Technical Expert Panel

The TEP, a group of six individuals with particular expertise in a variety of areas directly pertinent to this methods paper, was assembled to provide input regarding the scope and execution of the project. This group included representatives of the Food and Drug Administration (FDA) and the Centers for Medicare and Medicaid, an academic oncologist, a professional advocate for cancer treatment and research (representing the American Cancer Society), a patient advocate, a social scientist, and a Task Order Officer from the Agency for Healthcare Research and Quality (AHRQ). The Blue Cross Blue Shield Technology Evaluation Center Evidence-Based Practice Center (EPC) held teleconferences with the TEP, which provided input on the scope and Key Questions of this project and helped to define parameters for the methodology of the critical appraisal performed.

## Key Questions

After discussion with the TEP, two KQs were developed in an effort to evaluate evidence demonstrating progression-free survival (PFS) to be an outcome of importance to patients, or showing an association between PFS and other outcomes of importance to patients.

### KQ1 PFS as an Outcome of Importance to Patients

#### KQ1 When PFS is used as a primary clinical endpoint in treating patients with advanced cancers, is there direct evidence that knowing PFS impacts patient anxiety, depression, or psychological well-being? • If yes, does the manner of communicating PFS affect patient anxiety, depression, or psychological well-being?

KQ1 is focused on the direct causal relationship between knowledge of PFS status and the psychological impact on patients. This is an important question because PFS, when measured using imaging techniques, may occur as an asymptomatic event and may or may not be associated with changes in overall survival (OS). In these cases, PFS can be a stand-alone finding, and its greatest impact may be in promoting patient psychological well-being, depending on the information provided and a patient’s understanding of that information.

### KQ2 Associations of PFS with Quality of Life Outcomes

#### KQ2 For agents where PFS is the primary outcome measure being used to establish the performance (efficacy and safety) of a new drug, what evidence exists regarding the association of PFS with QOL or related outcomes, such as disease symptoms?

KQ2 is focused on the statistical association between PFS and QOL-related outcomes of importance to patients that might be observed as part of the results of a drug treatment trial. To answer KQ2 we identified a targeted sample of drugs. First, we chose the category of drugs used for treating patients with locally advanced or metastatic solid epithelial tumors (breast, ovary, colon, kidney, lung and head/neck). These high profile tumors represent an attractive study set because they exhibit variable speeds of progression, variable effect sizes, and differences in manifestations of symptoms. We identified drugs approved between 2005 and 2010, by one or more regulatory agencies, on the basis of trials using PFS as the primary endpoint for treatment of solid epithelial tumors. This timeframe was selected because it represented a unique period in time in which a relatively large number of drugs for treatment of advanced epithelial tumors were approved for use in the United States, Europe and/or Canada based on studies using PFS as an endpoint. The change in endpoints from an emphasis on objective response rate in the 1990s toward increased use of overall and progression-free survival in the 2000s is described in a series of publications by scientists at the FDA.2, 43, 44

The drugs identified from the selected time window included Avastin^®^, Ixempra^®^, Tykerb^®^, Vectibix^®^, Doxil^®^, Gemzar^®^, Yondelis^®^, Nexavar^®^, Votrient^®^, Sutent^®^, Tarceva^®^, and Taxotere^®^ (Appendix B). We chose these drugs that received regulatory approval based on PFS because we wanted to ensure authoritative vetting of the reliability of PFS measures used in the studies. For our purposes, regulatory approval was a proxy for the reliability of the PFS measure. Thus in the reports included in this review we were able to focus on whether studies demonstrated a causal relationship or statistical association between PFS and QOL or other patient-reported outcomes (PROs). The applicability of our findings regarding PFS and its association with QOL or other PROs may perhaps be restricted to this select group of drugs and the patients who received them. However, because this sample represents almost all drugs within our category of interest, bias was expected to be minimal. It is unlikely that drugs approved using PFS either before or subsequent to the time period studies would be likely to differ substantially.

To date, the FDA has rarely used PRO data as a factor in drug approvals or labeling for patients with advanced solid epithelial cancers; however, the agency has created clear guidance on requirements for studies of PRO.45 Measurement of meaningful differences in QOL in patients with advanced solid epithelial cancers may be a challenging task. In this population blinding is difficult, particularly if treatment is identifiable by unique toxicities.

Patients generally want to know the status of their disease and may report surprisingly good QOL even in the face of drug toxicity if there is an expectation that the drug has potential to change other outcomes for the better. For the purposes of understanding how knowledge of PFS might affect patients, we concluded measurement of global QOL is preferable to reports of specific symptoms. Our analysis did allow for PRO tools that included disease specific symptoms, these were identified in several reports studied, but the emphasis in this report was on broader measurements of patient well-being.

## Eligibility Criteria

Study inclusion/exclusion criteria for KQ1 and KQ2 are outlined in Table 1 and Table 2, respectively. This methods project focuses on the causal relationship (KQ1) or association (KQ2) between PFS and QOL or other PRO.

Table 1 Inclusion/exclusion criteria for KQ1

Category | Inclusion/Exclusion Criteria
Population | [underlined: Inclusion]: Patients with cancer
Interventions | [underlined: Inclusion]: Chemotherapy
Primary outcomes | [underlined: Inclusion]: PFS [underlined: Exclusion]: Studies without PFS as an endpoint
Comparator outcomes | [underlined: Inclusion]: Outcomes of importance to patients, including psychological well-being (or anxiety, depression) and quality of life
Time period | From 1999 to 2012
Setting | Oncology care settings for patients with neoplasms
Publication language | English or English language translations when available
Study designs | Clinical studies
Follow-up duration | All
Sample size | Studies of any size

PFS = progression-free survival

Table 2 Inclusion/exclusion criteria for KQ2

Category | Inclusion/Exclusion Criteria
Population | [underlined: Inclusion]: Patients with advanced solid epithelial cancers studied as part of a randomized clinical trial for the following targeted drugs: Avastin, Ixempra, Tykerb, Vectibix, Doxil, Gemzar, Yondelis, Nexavar, Votrient, Sutent, Tarceva, Taxotere) (see Appendix B)
Interventions | [underlined: Inclusion]: Chemotherapy using a drug approved for use by a U.S. Canadian, or European regulatory body based on PFS outcomes
Primary outcomes | [underlined: Inclusion]: PFS [underlined: Exclusion]: Studies not including PFS Note: Studies in which a drug also improves OS will [underlined: not] be excluded
Comparator outcomes | [underlined: Inclusion]: Outcomes of importance to patients, including psychological well-being (or anxiety, depression) and quality of life
Time period | 2004 to 2012
Setting | Oncology care settings for patients with advanced solid epithelial tumors
Publication language | English or English language translations when available
Study designs | Prospective randomized clinical trials
Follow-up duration | All
Sample size | Studies of any size

PFS = progression-free survival; OS = overall survival

As noted in the Background chapter, in contrast to a traditional comparison of interventions, PFS is an outcome, and as such it cannot be preselected or randomized as part of a prospective study. Thus, a new parameter appears in the inclusion/exclusion criteria; that is, “comparator outcomes,” which is a modification of the traditional population, intervention, comparator, timing, and setting (PICOTS) framework. The comparator outcomes of interest are those of importance to patients, such as QOL and psychological well-being.

## Literature Search

### Published Literature

Literature searches were conducted in the following databases:

- MEDLINE^®^ (via PubMed)
- Embase^®^
- Cochrane Central Register of Controlled Trials (CENTRAL)

The research librarian, in collaboration with the project team, developed and implemented search strategies designed to identify evidence relevant to each key question. Appendix B provides the actual terms employed in the search strategy.

To address KQ1, a comprehensive search was developed that would find any article looking for a causal relationship between knowing PFS status and outcomes of importance to patients, in particular those that affected psychological states (see KQ1, PFS as an Outcome of Importance to Patients). Databases were queried using search terms such as PFS and psychological, anxiety, and depression, in combination with terms for cancer. Accepted study designs included randomized controlled trials, observational studies, case studies, or other clinical studies. The timeframe (1999 to 2012) was selected because it represents a transition period in drug approvals, in which the FDA moved away from use of response rate or time to progression toward an increased use of OS or PFS.2,43 Because input from the TEP suggested there would be few, if any, publications addressing KQ1, the search criteria were deliberately broad and include all tumors and most types of published studies for use as evidence, including randomized prospective clinical trials, observational studies, and case series. Editorials, commentaries, and reviews were not included as evidence, but may have contributed additional references or to the background information.

For KQ2, a targeted search strategy included the identified drugs of interest—drugs approved for treatment of advanced solid epithelial tumors based on PFS as a primary endpoint (see KQ2, Associations of PFS with Outcomes of Importance to Patients) and QOL. The search encompassed the years 2004 to 2012 and as noted above was aimed at identifying studies that included drugs approved between 2005 and 2010 (Appendix C), a period of time in which a number of drugs were approved using PFS as the primary endpoint in the newly formed Office of Oncology Drug Products at the FDA and/or by European and Canadian regulators.

The literature searches for KQs 1 and 2 were restricted to the study of humans in the English language, with the exception of published articles in other languages for which English translations were available. Previous studies have shown that excluding non–English-language studies has little impact on conclusions relative to the resources required for translation.46, 47 The literature search was updated on July 3, 2012.

### Gray Literature

The gray literature was searched for relevant studies that met the inclusion/exclusion criteria. For the purposes of this methods project, the gray literature comprises information that is not controlled by commercial publishing, including abstracts presented at major oncology meetings (e.g., the National Comprehensive Cancer Network Outcomes Database Abstracts, the Annual Congress or the American Society of Clinical Oncology Annual Meeting); U.S. regulatory documents (e.g., guidance documents on cancer endpoints and PROs, public summaries of FDA meetings on cancer endpoints or FDA new drug approval briefings packages), meeting transcripts and materials, appeals, and clinical reviews; clinical trial registries (ClinicalTrials.gov), and documents developed and posted by European and Canadian drug regulating agencies. Because unpublished literature was not used as evidence in this project, the gray literature was used to identify potential publications in progress and for background information.

## Citation Screening

Articles obtained from the searches were uploaded to an EndNote^®^ (Thomson Reuters Corporation, New York, United States) reference manager database and then transferred to DistillerSR^®^ (Evidence Partners Inc., Ottawa, Canada) software for study eligibility screening. Using six preset questions that reflected the inclusion criteria, two reviewers independently screened titles and abstracts, marking each of the questions as: (1) yes (eligible for full-text screening); (2) no (ineligible for inclusion); or (3) uncertain (include in full-text screening to resolve eligibility). DistillerSR^®^ provided a report on reviewer discrepancies, which were resolved by discussion and consensus opinion; a third reviewer was consulted as needed.

Using a second set of three selection questions, two reviewers independently screened full-text articles using the same approach as above to determine eligibility for data abstraction. The title/abstract and full-text screening questions are presented in Appendix D. Although the title/abstract screening and full-text screening questions used “PRO or QOL” as the pivotal selection terms, for KQ1, reviewers included articles with reference to changes in any psychological state, such as anxiety, mood, or depression, as outcomes of importance to compare to PFS. The logic for considering QOL and, in particular, psychological outcomes is described above (see Background, PFS as a Health Outcome). For KQ2, reviewers included articles with any reference to changes in the above psychological states, plus QOL, disease symptoms, or any similar type of outcome of importance to patients.

## Data Extraction

Articles were distributed among the team members for abstraction. A Microsoft Excel^®^ spreadsheet was created and used for abstracting information from the eligible studies. Each article was abstracted by a single reviewer, with 100 percent fact-checking being completed by a second reviewer. Discrepancies were resolved by discussion and, if necessary, a third opinion was sought. The abstraction form items are presented in Appendix E.

## Data Synthesis

The analysis of study data is qualitative only. No effort was made to pool results, and no quantitative assessment was performed. The unique features of the included studies were captured in separate tables describing study characteristics, treatment safety and efficacy, description of the QOL measurement, the extent of missing data and how the issue was addressed, the statistical analysis, and the description of the association between PFS and QOL or other PRO, such as disease symptoms.

A causal model, represented as a directed acyclic graph, was posited based on the associations expressed as plausible or likely by the TEP and also informed by the literature reviewed. This model is based on techniques described in Supplement 2 of a recently published draft AHRQ report.48

## Quality Assessment of Individual Studies

To prepare for the quality assessment of included studies, existing quality assessment tools were reviewed for their applicability to the association being evaluated. In this methods project, the relationship of interest was not a comparison of treatment effects, but instead, compared two outcomes: PFS (considered the primary outcome) and other outcomes of interest to patients (considered the comparator outcomes). Owing to the nature of this focus, none of the existing quality assessment tools was judged entirely appropriate to capture the potential biases associated with this type of comparison. Accordingly, a more general approach developed and applied by Turner et al.,49 was adopted for evaluation of internal bias (i.e., study quality). This approach entails “envisioning” an “idealized version” of a study that would be free of bias, and then compares the included study to the idealized one to identify potential sources of bias. This approach allows considering any unique aspects of questions and studies, and includes well-established sources of potential bias, including selection, performance, attrition, detection, and other sources.50–52 Taking this approach was further justified based on its applicability to observational studies.49 Using this approach, and with consensus among the study investigators, four additional items that specifically addressed the potential for bias in studies evaluating an association between PFS and QOL were added to the quality assessment criteria (see Appendix F).

For the quality assessment, the general qualitative principles described in the AHRQ “Methods Guide for Effectiveness and Comparative Effectiveness Reviews” chapter, “Assessing the Risk of Bias of Individual Studies in Systematic Reviews of Health Care Interventions” were applied.53 Narrative descriptions were developed to correspond to the quality assessment of excellent, fair, and poor quality studies (Table 3). The most critical sources of potential bias were deemed to be failure to blind, significant patient drop out, and failure to provide follow-through observations after progression of disease.54–56

Table 3 Definitions of overall study quality ratings

Study Quality | Quality Attributes
Excellent | Adequate blinding, minimal patient attrition (20% or less), no censoring at progression, and conformance with 12 or more additional positive quality factors (Table 9)
Fair | Adequate blinding, minimal patient attrition (20% or less), no censoring at progression, and conformance with 6 or more additional positive quality factors (Table 9)
Poor | No blinding and/or more than minimal patient attrition (more than 20%) and censoring at progression

## Strength of Evidence

The system published by Owens et al.57 for grading the strength of evidence was used to systematically describe the evidence in this methods project. The system considers four standard domains: risk of bias, consistency, directness, and precision. These allow for four possible grades: high, moderate, low, or insufficient.