# Peer Reviewers

- Charles Cleeland, Ph.D.
  McCullough Professor of Cancer Research
  Department of Symptom Research
  Division of Internal Medicine
  The University of Texas MD Anderson Cancer Center
  Houston, TX
- I. Craig Henderson, M.D.
  Adjunct Professor
  Department of Medicine (Hematology/Oncology)
  University of California San Francisco
  San Francisco, CA
- Lori Minasian, M.D., F.A.C.P.
  Chief of the Community Oncology and Prevention Trials Research Group Program
  National Cancer Institute
  National Institutes of Health
  Bethesda, MD
- Daniel Sargent, Ph.D.
  Primary Consulting Statistician
  Gastrointestinal Cancer Program
  Mayo Clinic Cancer Center
  Rochester, MN
- Sandra L. Wong, M.D.
  Associate Professor, Surgery
  University of Michigan Health System
  Ann Arbor, MI