# Technical Expert Panel

- Rosemarie Hakim, Ph.D.
  Senior Epidemiologist
  Centers for Medicare & Medicaid Services
  Baltimore, MD
- J. Leonard Lichtenfeld, M.D., M.A.C.P.
  Deputy Chief Medical Officer
  American Cancer Society
  Atlanta, GA
- Kathy D. Miller, M.D.
  Associate Professor of Medicine
  Indiana University School of Medicine
  Indianapolis, IN
- Mary Lou Smith, J.D., M.B.A.
  Co-Founder
  Research Advocacy Network
  Plano TX
- Rajeshwari Sridhara, Ph.D.
  Director, Division of Biometrics V
  Center for Drug Evaluation and Research
  U.S. Food and Drug Administration
  Silver Spring, MD
- Lynne Wagner, Ph.D.
  Associate Professor, Medical Social Sciences
  Northwestern University
  Feinberg School of Medicine
  Chicago, IL