# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Claudia J. Bonnell, M.L.S., B.S.N.; Jennifer Brock, M.P.H.; Lisa Garofalo, B.A.; Lisa Sarsany, M.A.; and Kathleen M. Ziegler, Pharm.D.