# Articles Excluded at Full-Text Screening by Reason

## Level 2, Form Full-Text Screening, -> EXCLUDE - ABSTRACT ONLY, FULL-TEXT NOT AVAILABLE..

Refid: 103 Estimating quality of life in advanced melanoma; A comparison of standard gamble, SF-36 mapped, and eortc QLQ-c30 mapped utilities. Batty AJ, Fisher D, Winn B, Wang Q, Tolley K, Rowen D. Level: 2, State: Excluded.
Refid: 162 Patient preferences for non-small cell lung cancer (NSCLC) treatments. Bridges JF, Mohamed A, Finnern HW, Woehl A, Hauber AB. Level: 2, State: Excluded.
Refid: 202 Time to deterioration (TTD) in patient-reported outcomes in phase 3 axis trial of axitinib vs sorafenib as second-line therapy for metastatic renal cell carcinoma (mRCC). Cella D, Escudier B, Rini B, Chen C, Bhattacharyya H, Tarazi J, Rosbrook B, Kim S, Motzer R. Level: 2, State: Excluded.
Refid: 232 Health-related quality of life (HRQOL) in 1st line non-squamous non-small cell lung cancer (NSCLC) patients in a real life setting: Bevacizumab-based versus non-bevacizumab based therapy in a european pilot study. Chouaid C, Bischoff HG, Vergnenegre A, Heigener DF, Taylor-Stokes G, Roughley A, Walzer S. Level: 2, State: Excluded.
Refid: 310 Asthenia and fatigue as potential biomarkers of sunitinib efficacy in metastatic renal cell carcinoma. Davis MP, Figlin RA, Hutson TE, Goldstein D, Li S, Perkins J, Motzer RJ. Level: 2, State: Excluded.
Refid: 326 Patient preference-based utility weights from the functional assessment of cancer therapy-general (FACT-G) in women with hormone receptor positive metastatic breast cancer receiving letrozole plus lapatinib or letrozole alone. Delea TE, Sofrygin O, Amonkar M. Level: 2, State: Excluded.
Refid: 396 Unresectable colorectal liver metastases treated by intraoperative radiofrequency ablation with or without resection: the ARF2003 study. Evrard S, Rivoire M, Arnaud JP, Lermite E, Bellera C, Mathoulin-Pelissier S, Fonck M, Brunet R, Becouarn Y, Lalet C. Level: 2, State: Excluded.
Refid: 496 Analysis of toxicity profile, Dose reduction and efficacy of sunitinib in metastatic renal cancer. Gonzalez-Perez C, Pajares-Hachero BI, Muros-de Fuentes B, Gonzalez-Contreras J, Gomez-Sanchez AI, Solano-Hernandez B. Level: 2, State: Excluded.
Refid: 563 How much do patients with renal cell carcinoma (RCC) value progression free survival in medical decision making?-results from a benefit-risk conjoint study. Hauber AB, Mohamed AF, Johnson FR, Neary MP. Level: 2, State: Excluded.
Refid: 679 Erlotinib maintenance therapy for non-small cell lung cancer preserves quality of life. Juhasz E, Kim JH, Stelmakh L, Cicenas S, Klingelschmitt G. Level: 2, State: Excluded.
Refid: 772 Efficacy of Biological Agents (BA) in metastatic Triple Negative Breast Cancer (TNBC): A systematic review. La Verde NM, Bramati A, Sburlati P, Galfrascoli E, Moretti A, Bianchi A, Girelli S, Piva S, Garassino MC, Farina G. Level: 2, State: Excluded.
Refid: 807 Sofrafenib versus sunitinib in metastatic renal cell carcinoma: Indirect comparison analysis. Leung HW, Chan AL. Level: 2, State: Excluded.
Refid: 1007 Ariadna study - Evaluation of symptoms on daily life and health-related quality of life (HRQOL) of patients with advanced non-small cell lung cancer (NSCLC). Oramas J, Cobo M, Paredes A, Arriola E, Sala M, Artal A, Girones R, Martinez MJ, Figueroa S, Domine M. Level: 2, State: Excluded.
Refid: 1144 An interim analysis of health-related quality of life (HRQOL) in patients with non-squamous non-small-cell lung cancer (NSNSCLC) receiving bevacizumab vs bevacizumab + pemetrexed for maintenance therapy in avaperl 1. Rittmeyer A, Chouaid C, Kim JH, Ahn MJ, Gorbunova V, Scherpereel A, Oramas J, Walzer S, Barlesi F. Level: 2, State: Excluded.
Refid: 1350 Utility elicitation study in the UK general public for late stage chronic lymphocytic leukemia. Tolley K, Goad C, Yi Y, Maroudas PA, Thompson G. Level: 2, State: Excluded.
Refid: 1370 Bevacizumab in combination with chemotherapy for the first-line treatment of metastatic colorectal cancer. Ubago R, Castillo MA, Flores S, Beltran C. Level: 2, State: Excluded.
Refid: 1434 A Q-twist analysis comparing panitumumab plus best supportive care (BSC) with bsc alone in patients with wild-type kras metastatic colorectal cancer. Wang J, Zhao Z, Sherrill B, Peeters M, Wiezorek J, Barber B. Level: 2, State: Excluded.
Refid: 1469 Tumour response, skin rash and health-related quality of life (HRQOL) - Post-HOC data from the IPASS study. Wu Y, Fukuoka M, Mok TSK, Saijo N, Thongprasert S, Yang JCH, Chu DT, Yang JJ, Rukazenkov Y. Level: 2, State: Excluded.
Refid: 1530 Improved progression-free survival does not translate into better quality of life in chronic lymphocytic leukaemia -results of the randomised EBMT-Intergroup study on the value of autologous transplantation. De Wreede LC, Watson M, Van Os M, Milligan D, Van Gelder M, Michallet M, Dreger P, Dearden CE, Cordonnier C, Leporrier M, Koza V, Homewood J, Corront B, Baerlocher GM, Herr W, Niederwieser DW, Sutton L, De Witte TM, Schetelig J. Level: 2, State: Excluded.
Refid: 1588 Independent radiologic review of OCEANS, a phase III trial of carboplatin, gemcitabine, and bevacizumab or placebo for the treatment of platinum-sensitive, recurrent epithelial ovarian, primary peritoneal, or fallopian tube cancer. Aghajanian C, Makhija S, Rutherford T, Sharma S, Nycum L, Sovak M, Nguyen H, Yi J, Husain A. Level: 2, State: Excluded.

## Level 2, Form Full-Text Screening, -> EXCLUDE - REVIEW

Refid: 110 Sunitinib in Advanced Renal Cell Carcinoma: Clinical Evidence. Bellmunt J. Level: 2, State: Excluded.
Refid: 231 Disparities at presentation, diagnosis, treatment, and survival in African American men, affected by prostate cancer. Chornokur G, Dalton K, Borysova ME, Kumar NB. Level: 2, State: Excluded.
Refid: 275 Targeted therapy for advanced renal cell carcinoma. Coppin C, Le L, Porzsolt F, Wilt T. Level: 2, State: Excluded.
Refid: 308 Temozolomide: A review of its use in the treatment of malignant gliomas, malignant melanoma and other advanced cancers. Darkes MJM, Plosker GL, Jarvis B. Level: 2, State: Excluded.
Refid: 347 Erlotinib monotherapy for the maintenance treatment of non-small cell lung cancer after previous platinum-containing chemotherapy: A NICE single technology appraisal. Dickson R, Bagust A, Boland A, Blundell M, Davis H, Dundar Y, Hockenhull J, Martin Saborido C, Oyee J, Ramani VS. Level: 2, State: Excluded.
Refid: 984 The European Medicines Agency review of pazopanib for the treatment of advanced renal cell carcinoma: Summary of the scientific assessment of the Committee for Medicinal Products for Human Use. Nieto M, Borregaard J, Ersboll J, Ten Bosch GJA, Van Zwieten-Boot B, Abadie E, Schellens JHM, Pignatti F. Level: 2, State: Excluded.
Refid: 1043 Panitumumab in Combination With Cytotoxic Chemotherapy for the Treatment of Metastatic Colorectal Carcinoma. Peeters M, Cohn A, Kohne CH, Douillard JY. Level: 2, State: Excluded.
Refid: 1145 Cetuximab in metastatic or recurrent head and neck cancer: the EXTREME trial. Rivera F, Garcia-Castano A, Vega N, Vega-Villegas ME, Gutierrez-Sanz L. Level: 2, State: Excluded.
Refid: 1437 Panitumumab: in metastatic colorectal cancer with wild-type KRAS. Weber J, McCormack PL. Level: 2, State: Excluded.
Refid: 1449 Bevacizumab in combination with fluoropyrimidine-based chemotherapy for the first-line treatment of metastatic colorectal cancer. Whyte S, Pandor A, Stevenson M, Rees A. Level: 2, State: Excluded.

## Level 2, Form Full-Text Screening, -> EXCLUDE - CONFERENCE PRESENTATION

Refid: 1208 Do hope, optimism and other psychological factors predict survival in patients with metastatic colorectal cancer?. Schofield P, Stockler M, Zannino D, Wong N, Ransom D, Moylan E, Simes J, Price T, Tebbutt N, Jefford M. Level: 2, State: Excluded.

## Level 2, Form Full-Text Screening, Does this study utilize one or more validated PRO/QoL tools to measure the PRO/QoL outcome(s) reported?... -> No-EXCLUDE

Refid: 24 Randomized trial of pegylated liposomal doxorubicin (PLD) plus carboplatin versus carboplatin in platinum-sensitive (PS) patients with recurrent epithelial ovarian or peritoneal carcinoma after failure of initial platinum-based chemotherapy (Southwest Oncology Group Protocol S0200). Alberts DS, Liu PY, Wilczynski SP, Clouser MC, Lopez AM, Michelin DP, Lanzotti VJ, Markman M. Level: 2, State: Excluded.
Refid: 35 Lapatinib and HER2 status: results of a meta-analysis of randomized phase III trials in metastatic breast cancer. Amir E, Ocana A, Seruga B, Freedman O, Clemons M. Level: 2, State: Excluded.
Refid: 131 Randomized study of Lapatinib alone or in combination with trastuzumab in women with ErbB2-positive, trastuzumab-refractory metastatic breast cancer. Blackwell KL, Burstein HJ, Storniolo AM, Rugo H, Sledge G, Koehler M, Ellis C, Casey M, Vukelja S, Bischoff J, Baselga J, O’Shaughnessy J. Level: 2, State: Excluded.
Refid: 252 Quality-of-life-adjusted survival comparison of sustained-release cytosine arabinoside versus intrathecal methotrexate for treatment of solid tumor neoplastic meningitis. Cole BF, Glantz MJ, Jaeckle KA, Chamberlain MC, Mackowiak JI. Level: 2, State: Excluded.
Refid: 384 Predictors of response to sequential sunitinib and the impact of prior VEGF-targeted drug washout in patients with metastatic clear-cell renal cell carcinoma. Elfiky AA, Cho DC, McDermott DF, Rosenberg JE, Fortner B, Antras L, Chen K, Sheng Duh M, Jayawant SS, Oh WK, Atkins MB, Choueiri TK. Level: 2, State: Excluded.
Refid: 453 Bevacizumab in combination with metronomic chemotherapy in patients with anthracycline- and taxane-refractory breast cancer. Garcia-Saenz JA, Martin M, Calles A, Bueno C, Rodriguez L, Bobokova J, Custodio A, Casado A, Diaz-Rubio E. Level: 2, State: Excluded.
Refid: 484 U.S. Food and Drug Administration approval: panitumumab for epidermal growth factor receptor-expressing metastatic colorectal carcinoma with progression following fluoropyrimidine-, oxaliplatin-, and irinotecan-containing chemotherapy regimens. Giusti RM, Shastri K, Pilaro AM, Fuchs C, Cordoba-Rodriguez R, Koti K, Rothmann M, Men AY, Zhao H, Hughes M, Keegan P, Weiss KD, Pazdur R. Level: 2, State: Excluded.
Refid: 485 FDA drug approval summary: panitumumab (Vectibix). Giusti RM, Shastri KA, Cohen MH, Keegan P, Pazdur R. Level: 2, State: Excluded.
Refid: 529 Efficacy and safety of bevacizumab plus chemotherapy in Chinese patients with metastatic colorectal cancer: a randomized phase III ARTIST trial. Guan ZZ, Xu JM, Luo RC, Feng FY, Wang LW, Shen L, Yu SY, Ba Y, Liang J, Wang D, Qin SK, Wang JJ, He J, Qi C, Xu RH. Level: 2, State: Excluded.
Refid: 571 A randomized phase IIIB trial of chemotherapy, bevacizumab, and panitumumab compared with chemotherapy and bevacizumab alone for metastatic colorectal cancer. Hecht JR, Mitchell E, Chidiac T, Scroggin C, Hagenstad C, Spigel D, Marshall J, Cohn A, McCollum D, Stella P, Deeter R, Shahin S, Amado RG. Level: 2, State: Excluded.
Refid: 575 Second-line erlotinib in patients with advanced non-small-cell lung cancer: Subgroup analyses from the TRUST study. Heigener DF, Wu YL, van Zandwijk N, Mali P, Horwood K, Reck M. Level: 2, State: Excluded.
Refid: 629 Bevacizumab plus irinotecan, fluorouracil, and leucovorin for metastatic colorectal cancer. Hurwitz H, Fehrenbacher L, Novotny W, Cartwright T, Hainsworth J, Heim W, Berlin J, Baron A, Griffing S, Holmgren E, Ferrara N, Fyfe G, Rogers B, Ross R, Kabbinavar F. Level: 2, State: Excluded.
Refid: 630 The clinical benefit of bevacizumab in metastatic colorectal cancer is independent of K-ras mutation status: analysis of a phase III study of bevacizumab with chemotherapy in previously untreated metastatic colorectal cancer. Hurwitz HI, Yi J, Ince W, Novotny WF, Rosen O. Level: 2, State: Excluded.
Refid: 637 Clinical outcome of panitumumab for metastatic colorectal cancer with wild-type KRAS status: a meta-analysis of randomized clinical trials. Ibrahim EM, Abouelkhair KM. Level: 2, State: Excluded.
Refid: 643 Quality-adjusted survival in a crossover trial of letrozole versus tamoxifen in postmenopausal women with advanced breast cancer. Irish W, Sherrill B, Cole B, Gard C, Glendenning GA, Mouridsen H. Level: 2, State: Excluded.
Refid: 666 Approval summary for erlotinib for treatment of patients with locally advanced or metastatic non-small cell lung cancer after failure of at least one prior chemotherapy regimen. Johnson JR, Cohen M, Sridhara R, Chen YF, Williams GM, Duan J, Gobburu J, Booth B, Benson K, Leighton J, Hsieh LS, Chidambaram N, Zimmerman P, Pazdur R. Level: 2, State: Excluded.
Refid: 667 Lapatinib combined with letrozole versus letrozole and placebo as first-line therapy for postmenopausal hormone receptor-positive metastatic breast cancer. Johnston S, Pippen J Jr, Pivot X, Lichinitser M, Sadeghi S, Dieras V, Gomez HL, Romieu G, Manikhas A, Kennedy MJ, Press MF, Maltzman J, Florance A, O’Rourke L, Oliva C, Stein S, Pegram M. Level: 2, State: Excluded.
Refid: 680 Addition of Bevacizumab to Fluorouracil-Based First-Line Treatment of Metastatic Colorectal Cancer: Pooled Analysis of Cohorts of Older Patients From Two Randomized Clinical Trials. Kabbinavar FF, Hurwitz HI, Yi J, Sarkar S, Rosen O. Level: 2, State: Excluded.
Refid: 808 Multikinase inhibitors in metastatic renal cell carcinoma: indirect comparison meta-analysis. Leung HWC, Chan ALF. Level: 2, State: Excluded.
Refid: 823 VEGF pathway-targeted therapy for advanced renal cell carcinoma: A meta-analysis of randomized controlled trials. Liu F, Chen X, Peng E, Guan W, Li Y, Hu Z, Ye Z, Zhuang Q. Level: 2, State: Excluded.
Refid: 870 Single agent carboplatin versus carboplatin plus pegylated liposomal doxorubicin in recurrent ovarian cancer: Final survival results of a SWOG (S0200) phase 3 randomized trial. Markman M, Moon J, Wilczynski S, Lopez AM, Rowland KM Jr, Michelin DP, Lanzotti VJ, Anderson GL, Alberts DS. Level: 2, State: Excluded.
Refid: 883 SABRE-B: an evaluation of paclitaxel and bevacizumab with or without sunitinib as first-line treatment of metastatic breast cancer. Mayer EL, Dhakil S, Patel T, Sundaram S, Fabian C, Kozloff M, Qamar R, Volterra F, Parmar H, Samant M, Burstein HJ. Level: 2, State: Excluded.
Refid: 914 Phase III study of bevacizumab plus docetaxel compared with placebo plus docetaxel for the first-line treatment of human epidermal growth factor receptor 2-negative metastatic breast cancer. Miles DW, Chan A, Dirix LY, Cortes J, Pivot X, Tomczak P, Delozier T, Sohn JH, Provencher L, Puglisi F, Harbeck N, Steger GG, Schneeweiss A, Wardley AM, Chlistalla A, Romieu G. Level: 2, State: Excluded.
Refid: 933 Early adjuvant radiotherapy toward long-term survival and better quality of life for craniopharyngiomas--a study in single institute. Moon SH, Kim IH, Park SW, Kim I, Hong S, Park CI, Wang KC, Cho BK. Level: 2, State: Excluded.
Refid: 971 Efficacy and safety of sorafenib in patients with advanced renal cell carcinoma with and without prior cytokine therapy, a subanalysis of TARGET. Negrier S, Jager E, Porta C, McDermott D, Moore M, Bellmunt J, Anderson S, Cihon F, Lewis J, Escudier B, Bukowski R. Level: 2, State: Excluded.
Refid: 981 Management of spinal metastases from renal cell carcinoma using stereotactic body radiotherapy. Nguyen QN, Shiu AS, Rhines LD, Wang H, Allen PK, Wang XS, Chang EL. Level: 2, State: Excluded.
Refid: 1055 Erlotinib as maintenance therapy in patients with advanced non-small cell lung cancer: A pooled analysis of three randomized trials. Petrelli F, Borgonovo K, Cabiddu M, Barni S. Level: 2, State: Excluded.
Refid: 1068 Capecitabine and celecoxib as second-line treatment of advanced pancreatic and biliary tract cancers. Pino MS, Milella M, Gelibter A, Sperduti I, De Marco S, Nuzzo C, Bria E, Carpanese L, Ruggeri EM, Carlini P, Cognetti F. Level: 2, State: Excluded.
Refid: 1089 Pegylated liposomal Doxorubicin and Carboplatin compared with Paclitaxel and Carboplatin for patients with platinum-sensitive ovarian cancer in late relapse. Pujade-Lauraine E, Wagner U, Aavall-Lundqvist E, Gebski V, Heywood M, Vasey PA, Volgger B, Vergote I, Pignata S, Ferrero A, Sehouli J, Lortholary A, Kristensen G, Jackisch C, Joly F, Brown C, Le Fur N, du Bois A. Level: 2, State: Excluded.
Refid: 1142 Comparative effectiveness of axitinib versus sorafenib in advanced renal cell carcinoma (AXIS): A randomised phase 3 trial. Rini BI, Escudier B, Tomczak P, Kaprin A, Szczylik C, Hutson TE, Michaelson MD, Gorbunova VA, Gore ME, Rusakov IG, Negrier S, Ou YC, Castellano D, Lim HY, Uemura H, Tarazi J, Cella D, Chen C, Rosbrook B, Kim S, Motzer RJ. Level: 2, State: Excluded.
Refid: 1151 RIBBON-1: randomized, double-blind, placebo-controlled, phase III trial of chemotherapy with or without bevacizumab for first-line treatment of human epidermal growth factor receptor 2-negative, locally recurrent or metastatic breast cancer. Robert NJ, Dieras V, Glaspy J, Brufsky AM, Bondarenko I, Lipatov ON, Perez EA, Yardley DA, Chan SYT, Zhou X, Phan S-C, O’Shaughnessy J. Level: 2, State: Excluded.
Refid: 1184 Balancing risk and benefit for first-line treatment of metastatic colorectal cancer: a graphic communication tool for patients and physicians. Sanatani MS, Vincent MD. Level: 2, State: Excluded.
Refid: 1201 Biweekly high-dose gemcitabine alone or in combination with capecitabine in patients with metastatic pancreatic adenocarcinoma: a randomized phase II trial. Scheithauer W, Schull B, Ulrich-Pur H, Schmid K, Raderer M, Haider K, Kwasny W, Depisch D, Schneeweiss B, Lang F, Kornek GV. Level: 2, State: Excluded.
Refid: 1217 Lapatinib plus letrozole as first-line therapy for HER-2+ hormone receptor-positive metastatic breast cancer. [Erratum appears in Oncologist. 2010;15(3):327 Note: Schwarzberg, Lee S [corrected to Schwartzberg, Lee S]]. Schwartzberg LS, Franco SX, Florance A, O’Rourke L, Maltzman J, Johnston S. Level: 2, State: Excluded.
Refid: 1241 Erlotinib in previously treated non-small-cell lung cancer. Shepherd FA, Rodrigues Pereira J, Ciuleanu T, Tan EH, Hirsh V, Thongprasert S, Campos D, Maoleekoonpiroj S, Smylie M, Martins R, van Kooten M, Dediu M, Findlay B, Tu D, Johnston D, Bezjak A, Clark G, Santabarbara P, Seymour L. Level: 2, State: Excluded.
Refid: 1322 A nonradiation-containing, intermediate-dose methotrexate regimen for elderly patients with primary central nervous system lymphoma. Taoka K, Okoshi Y, Sakamoto N, Takano S, Matsumura A, Hasegawa Y, Chiba S. Level: 2, State: Excluded.
Refid: 1360 1. Sorafenib in advanced clear-cell renal-cell carcinoma. Escudier B, Eisen T, Stadler WM, Szczylik C, Oudard S, Siebels M, Negrier S, Chevreau C, Solska E, Desai AA, Rolland F, Demkow T, Hutson TE, Gore M, Freeman S, Schwartz B, Shan M, Simantov R, Bukowski RM, TARGET Study Group, Department of Medicine, Institut Gustave Roussy, Villejuif, France. Trump DL. Level: 2, State: Excluded.
Refid: 1378 Magnitude of benefit of the addition of bevacizumab (BEVA) to first-line chemotherapy (CT) for advanced/metastatic colorectal cancer (MCRC): Meta-analysis of randomized clinical trials. Vaccaro V, Cuppone F, Loupakis F, Milella M, Carlini P, Nistico C, Falcone A, Terzoli E, Cognetti F, Bria E. Level: 2, State: Excluded.
Refid: 1424 Correlation between development of rash and efficacy in patients treated with the epidermal growth factor receptor tyrosine kinase inhibitor erlotinib in two large phase III studies. Wacker B, Nagrani T, Weinberg J, Witt K, Clark G, Cagnoni PJ. Level: 2, State: Excluded.
Refid: 1433 A Q-TWiST analysis comparing panitumumab plus best supportive care (BSC) with BSC alone in patients with wild-type KRAS metastatic colorectal cancer. Wang J, Zhao Z, Barber B, Sherrill B, Peeters M, Wiezorek J. Level: 2, State: Excluded.
Refid: 1488 Survival benefits from lapatinib therapy in women with HER2-overexpressing breast cancer: a systematic review. Yip AY, Tse LA, Ong EY, Chow LW. Level: 2, State: Excluded.
Refid: 1507 Ixabepilone plus capecitabine for metastatic breast cancer progressing after anthracycline and taxane treatment. Thomas ES, Gomez HL, Li RK, Chung HC, Fein LE, Chan VF, Jassem J, Pivot XB, Klimovsky JV, de Mendoza FH, Xu B, Campone M, Lerzo GL, Peck RA, Mukhopadhyay P, Vahdat LT, Roche HH. Level: 2, State: Excluded.
Refid: 1509 beta-Tubulin-II expression strongly predicts outcome in patients receiving induction chemotherapy for locally advanced squamous carcinoma of the head and neck: a companion analysis of the TAX 324 trial. Cullen KJ, Schumaker L, Nikitakis N, Goloubeva O, Tan M, Sarlis NJ, Haddad RI, Posner MR. Level: 2, State: Excluded.
Refid: 1514 Induction chemotherapy with cisplatin and fluorouracil alone or in combination with docetaxel in locally advanced squamous-cell cancer of the head and neck: long-term results of the TAX 324 randomised phase 3 trial. Lorch JH, Goloubeva O, Haddad RI, Cullen K, Sarlis N, Tishler R, Tan M, Fasciano J, Sammartino DE, Posner MR. Level: 2, State: Excluded.
Refid: 1516 Sequential therapy for the locally advanced larynx and hypopharynx cancer subgroup in TAX 324: survival, surgery, and organ preservation. Posner MR, Norris CM, Wirth LJ, Shin DM, Cullen KJ, Winquist EW, Blajman CR, Mickiewicz EA, Frenette GP, Plinar LF, Cohen RB, Steinbrenner LM, Freue JM, Gorbunova VA, Tjulandin SA, Raez LE, Adkins DR, Tishler RB, Roessner MR, Haddad RI. Level: 2, State: Excluded.
Refid: 1518 Cisplatin, fluorouracil, and docetaxel in unresectable head and neck cancer. Vermorken JB, Remenar E, van Herpen C, Gorlia T, Mesia R, Degardin M, Stewart JS, Jelic S, Betka J, Preiss JH, van den Weyngaert D, Awada A, Cupissol D, Kienzer HR, Rey A, Desaunois I, Bernier J, Lefebvre JL. Level: 2, State: Excluded.
Refid: 1596 Ixabepilone plus capecitabine in advanced breast cancer patients with early relapse after adjuvant anthracyclines and taxanes: A pooled subset analysis of two phase III studies. Jassem J, Fein L, Karwal M, Campone M, Peck R, Poulart V, Vahdat L. Level: 2, State: Excluded.
Refid: 1600 Phase II escalation study of sorafenib in patients with metastatic renal cell carcinoma who have been previously treated with anti-angiogenic treatment. Mancuso A, Di Paola ED, Leone A, Catalano A, Calabro F, Cerbone L, Zivi A, Messina C, Alonso S, Vigna L, Caristo R, Sternberg CN. Level: 2, State: Excluded.
Refid: 1615 OCEANS: A Randomized, Double-Blind, Placebo-Controlled Phase III Trial of Chemotherapy With or Without Bevacizumab in Patients With Platinum-Sensitive Recurrent Epithelial Ovarian, Primary Peritoneal, or Fallopian Tube Cancer. Aghajanian C, Blank SV, Goff BA, Judson PL, Teneriello MG, Husain A, Sovak MA, Yi J, Nycum LR. Level: 2, State: Excluded.
Refid: 1616 CA-125 can be part of the tumour evaluation criteria in ovarian cancer trials: experience of the GCIG CALYPSO trial. Alexandre J, Brown C, Coeffic D, Raban N, Pfisterer J, Maenpaa J, Chalchal H, Fitzharris B, Volgger B, Vergote I, Pisano C, Ferrero A, Pujade-Lauraine E. Level: 2, State: Excluded.
Refid: 1618 Bevacizumab based chemotherapy in first line treatment of HER2 negative metastatic breast cancer: results of a Moroccan observational institutional study. Boulaamane L, Boutayeb S, Errihani H. Level: 2, State: Excluded.
Refid: 1620 Second-line bevacizumab-containing therapy in patients with triple-negative breast cancer: subgroup analysis of the RIBBON-2 trial. Brufsky A, Valero V, Tiangco B, Dakhil S, Brize A, Rugo HS, Rivera R, Duenne A, Bousfoul N, Yardley DA. Level: 2, State: Excluded.
Refid: 1621 Sunitinib followed by sorafenib or vice versa for metastatic renal cell carcinoma--data from the Czech registry. Buchler T, Klapka R, Melichar B, Brabec P, Dusek L, Vyzula R, Abrahamova J. Level: 2, State: Excluded.
Refid: 1624 First-line XELOX plus bevacizumab followed by XELOX plus bevacizumab or single-agent bevacizumab as maintenance therapy in patients with metastatic colorectal cancer: the phase III MACRO TTD study. Diaz-Rubio E, Gomez-Espana A, Massuti B, Sastre J, Abad A, Valladares M, Rivera F, Safont MJ, Martinez de Prado P, Gallen M, Gonzalez E, Marcuello E, Benavides M, Fernandez-Martos C, Losa F, Escudero P, Arrivi A, Cervantes A, Duenas R, Lopez-Ladron A, Lacasta A, Llanos M, Tabernero JM, Anton A, Aranda E. Level: 2, State: Excluded.
Refid: 1628 Carboplatin and pegylated liposomal doxorubicin versus carboplatin and paclitaxel in partially platinum-sensitive ovarian cancer patients: results from a subset analysis of the CALYPSO phase III trial. Gladieff L, Ferrero A, De Rauglaudre G, Brown C, Vasey P, Reinthaller A, Pujade-Lauraine E, Reed N, Lorusso D, Siena S, Helland H, Elit L, Mahner S. Level: 2, State: Excluded.
Refid: 1630 A Randomized, Phase II Trial of Standard Triweekly Compared with Dose-Dense Biweekly Capecitabine Plus Oxaliplatin Plus Bevacizumab as First-Line Treatment for Metastatic Colorectal Cancer: XELOX-A-DVS (Dense Versus Standard). Hurwitz H, Mitchell EP, Cartwright T, Kwok A, Hu S, McKenna E, Patt YZ. Level: 2, State: Excluded.
Refid: 1633 Gastrointestinal perforation associated with bevacizumab use in metastatic colorectal cancer: results from a large treatment observational cohort study. Kabbinavar FF, Flynn PJ, Kozloff M, Ashby MA, Sing A, Barr CE, Grothey A. Level: 2, State: Excluded.
Refid: 1635 Randomized phase 2b study of pralatrexate versus erlotinib in patients with stage IIIB/IV non-small-cell lung cancer (NSCLC) after failure of prior platinum-based therapy. Kelly K, Azzoli CG, Zatloukal P, Albert I, Jiang PY, Bodkin D, Pereira JR, Juhasz E, Iannotti NO, Weems G, Koutsoukos T, Patel JD. Level: 2, State: Excluded.
Refid: 1636 Pharmacogenetic analysis of BR.21, a placebo-controlled randomized phase III clinical trial of erlotinib in advanced non-small cell lung cancer. Liu G, Cheng D, Ding K, Le Maitre A, Liu N, Patel D, Chen Z, Seymour L, Shepherd FA, Tsao MS. Level: 2, State: Excluded.
Refid: 1637 Phase II study of NGR-hTNF in combination with doxorubicin in relapsed ovarian cancer patients. Lorusso D, Scambia G, Amadio G, di Legge A, Pietragalla A, De Vincenzo R, Masciullo V, Di Stefano M, Mangili G, Citterio G, Mantori M, Lambiase A, Bordignon C. Level: 2, State: Excluded.
Refid: 1644 Trabectedin plus pegylated liposomal doxorubicin (PLD) versus PLD in recurrent ovarian cancer: Overall survival analysis. Monk BJ, Herzog TJ, Kaye SB, Krasner CN, Vermorken JB, Muggia FM, Pujade-Lauraine E, Park YC, Parekh TV, Poveda AM. Level: 2, State: Excluded.
Refid: 1650 Bevacizumab is equally effective and no more toxic in elderly patients with advanced colorectal cancer: a subgroup analysis from the AGITG MAX trial: an international randomised controlled trial of Capecitabine, Bevacizumab and Mitomycin C. Price TJ, Zannino D, Wilson K, Simes RJ, Cassidy J, Van Hazel GA, Robinson BA, Broad A, Ganju V, Ackland SP, Tebbutt NC. Level: 2, State: Excluded.
Refid: 1653 Erlotinib versus standard chemotherapy as first-line treatment for European patients with advanced EGFR mutation-positive non-small-cell lung cancer (EURTAC): a multicentre, open-label, randomised phase 3 trial. Rosell R, Carcereny E, Gervais R, Vergnenegre A, Massuti B, Felip E, Palmero R, Garcia-Gomez R, Pallares C, Sanchez JM, Porta R, Cobo M, Garrido P, Longo F, Moran T, Insa A, De Marinis F, Corre R, Bover I, Illiano A, Dansin E, de Castro J, Milella M, Reguart N, Altavilla G, Jimenez U, Provencio M, Moreno MA, Terrasa J, Munoz-Langa J, Valdivia J, Isla D, Domine M, Molinier O, Mazieres J, Baize N, Garcia-Campelo R, Robinet G, Rodriguez-Abreu D, Lopez-Vivanco G, Gebbia V, Ferrera-Delgado L, Bombaron P, Bernabe R, Bearz A, Artal A, Cortesi E, Rolfo C, Sanchez-Ronco M, Drozdowskyj A, Queralt C, de Aguirre I, Ramirez JL, Sanchez JJ, Molina MA, Taron M, Paz-Ares L. Level: 2, State: Excluded.
Refid: 1654 Phase III trial of cetuximab, bevacizumab, and 5-fluorouracil/leucovorin vs. FOLFOX-bevacizumab in colorectal cancer. Saltz L, Badarinath S, Dakhil S, Bienvenu B, Harker WG, Birchfield G, Tokaz LK, Barrera D, Conkling PR, O’Rourke MA, Richards DA, Reidy D, Solit D, Vakiani E, Capanu M, Scales A, Zhan F, Boehm KA, Asmar L, Cohn A. Level: 2, State: Excluded.
Refid: 1655 Sunitinib Plus Erlotinib Versus Placebo Plus Erlotinib in Patients With Previously Treated Advanced Non-Small-Cell Lung Cancer: A Phase III Trial. Scagliotti GV, Krzakowski M, Szczesna A, Strausz J, Makhson A, Reck M, Wierzbicki RF, Albert I, Thomas M, Miziara JE, Papai ZS, Karaseva N, Thongprasert S, Portulas ED, von Pawel J, Zhang K, Selaru P, Tye L, Chao RC, Govindan R. Level: 2, State: Excluded.
Refid: 1657 Randomised phase-II trial of CAPIRI (capecitabine, irinotecan) plus bevacizumab vs FOLFIRI (folinic acid, 5-fluorouracil, irinotecan) plus bevacizumab as first-line treatment of patients with unresectable/metastatic colorectal cancer (mCRC). Souglakos J, Ziras N, Kakolyris S, Boukovinas I, Kentepozidis N, Makrantonakis P, Xynogalos S, Christophyllakis C, Kouroussis C, Vamvakas L, Georgoulias V, Polyzos A. Level: 2, State: Excluded.
Refid: 1659 Maintenance of Clinical Efficacy After Dose Reduction of Ixabepilone Plus Capecitabine in Patients With Anthracycline- and Taxane-Resistant Metastatic Breast Cancer: A Retrospective Analysis of Pooled Data from 2 Phase III Randomized Clinical Trials. Valero V, Vrdoljak E, Xu B, Thomas E, Gomez H, Manikhas A, Medina C, Li RK, Ro J, Bosserman L, Vahdat L, Mukhopadhyay P, Opatt D, Sparano JA. Level: 2, State: Excluded.
Refid: 1689 Overall Survival Benefit With Lapatinib in Combination With Trastuzumab for Patients With Human Epidermal Growth Factor Receptor 2-Positive Metastatic Breast Cancer: Final Results From the EGF104900 Study. Blackwell KL, Burstein HJ, Storniolo AM, Rugo HS, Sledge G, Aktan G, Ellis C, Florance A, Vukelja S, Bischoff J, Baselga J, O’Shaughnessy J. Level: 2, State: Excluded.
Refid: 1722 Q-TWiST analysis to estimate overall benefit for patients with metastatic renal cell carcinoma treated in a phase III trial of sunitinib vs interferon-alpha. Patil S, Figlin RA, Hutson TE, Michaelson MD, Negrier S, Kim ST, Huang X, Motzer RJ. Level: 2, State: Excluded.
Refid: 1739 Efficacy and safety of sorafenib in advanced renal cell carcinoma patients: Results from a long-term study. Yang L, Shi L, Fu Q, Xiong H, Zhang M, Yu S. Level: 2, State: Excluded.

## Level 2, Form Full-Text Screening, Does this study report a direct association between PFS and a PRO/QOL outcome? -> No-EXCLUDE

Refid: 73 Health-related quality of life in patients with advanced colorectal cancer treated with cetuximab: overall and KRAS-specific results of the NCIC CTG and AGITG CO.17 Trial. Au HJ, Karapetis CS, O’Callaghan CJ, Tu D, Moore MJ, Zalcberg JR, Kennecke H, Shapiro JD, Koski S, Pavlakis N, Charpentier D, Wyld D, Jefford M, Knight GJ, Magoski NM, Brundage MD, Jonker DJ. Level: 2, State: Excluded.
Refid: 87 Biweekly carboplatin/gemcitabine in patients with advanced urothelial cancer who are unfit for cisplatin-based chemotherapy: report of efficacy, quality of life and geriatric assessment. Bamias A, Lainakis G, Kastritis E, Antoniou N, Alivizatos G, Koureas A, Chrisofos M, Skolarikos A, Karayiotis E, Dimopoulos MA. Level: 2, State: Excluded.
Refid: 108 Patient-reported outcomes in a phase iii study of everolimus versus placebo in patients with metastatic carcinoma of the kidney that has progressed on vascular endothelial growth factor receptor tyrosine kinase inhibitor therapy. Beaumont JL, Butt Z, Baladi J, Motzer RJ, Haas T, Hollaender N, Kay A, Cella D. Level: 2, State: Excluded.
Refid: 114 Health-related quality of life in patients with metastatic colorectal cancer treated with panitumumab in first- or second-line treatment. Bennett L, Zhao Z, Barber B, Zhou X, Peeters M, Zhang J, Xu F, Wiezorek J, Douillard JY. Level: 2, State: Excluded.
Refid: 152 Multicenter phase II trial of temozolomide in patients with glioblastoma multiforme at first relapse. Brada M, Hoang-Xuan K, Rampling R, Dietrich PY, Dirix LY, Macdonald D, Heimans JJ, Zonnenberg BA, Bravo-Marques JM, Henriksson R, Stupp R, Yue N, Bruner J, Dugan M, Rao S, Zaknoen S. Level: 2, State: Excluded.
Refid: 167 Effects of sorafenib on symptoms and quality of life: results from a large randomized placebo-controlled study in renal cancer. Bukowski R, Cella D, Gondek K, Escudier B, Sorafenib TCTG. Level: 2, State: Excluded.
Refid: 189 The prognostic effects of performance status and quality of life scores on progression-free survival and overall survival in advanced ovarian cancer. Carey MS, Bacon M, Tu D, Butler L, Bezjak A, Stuart GC. Level: 2, State: Excluded.
Refid: 200 Baseline quality of life as a prognostic survival tool in patients receiving sunitinib for metastatic renal cell carcinoma. Cella D, Bushmakin AG, Cappelleri JC, Charbonneau C, Michaelson MD, Motzer RJ. Level: 2, State: Excluded.
Refid: 201 Quality of Life Predicts Progression-Free Survival in Patients With Metastatic Renal Cell Carcinoma Treated With Sunitinib Versus Interferon Alfa. Cella D, Cappelleri JC, Bushmakin A, Charbonneau C, Li JZ, Kim ST, Chen I, Michaelson MD, Motzer RJ. Level: 2, State: Excluded.
Refid: 204 Quality of life in patients with metastatic renal cell carcinoma treated with sunitinib or interferon alfa: results from a phase III randomized trial. Cella D, Li JZ, Cappelleri JC, Bushmakin A, Charbonneau C, Kim ST, Chen I, Motzer RJ. Level: 2, State: Excluded.
Refid: 260 Baseline physical functioning status of metastatic colorectal cancer patients predicts the overall survival but not the activity of a front-line oxaliplatin-fluoropyrimidine doublet. Comella P, Casaretti R, Manzo R, Sandomenico C, Licenziato M, Avallone A, Franco L. Level: 2, State: Excluded.
Refid: 285 Survival benefit with erlotinib maintenance therapy in patients with advanced non-small-cell lung cancer (NSCLC) according to response to first-line chemotherapy. Coudert B, Ciuleanu T, Park K, Wu YL, Giaccone G, Brugger W, Gopalakrishna P, Cappuzzo F. Level: 2, State: Excluded.
Refid: 313 Leucovorin and fluorouracil with or without oxaliplatin as first-line treatment in advanced colorectal cancer. de Gramont A, Figer A, Seymour M, Homerin M, Hmissi A, Cassidy J, Boni C, Cortes-Funes H, Cervantes A, Freyer G, Papamichael D, Le Bail N, Louvet C, Hendler D, de Braud F, Wilson C, Morvan F, Bonetti A. Level: 2, State: Excluded.
Refid: 315 Lung Cancer Symptom Scale outcomes in relation to standard efficacy measures: an analysis of the phase III study of pemetrexed versus docetaxel in advanced non-small cell lung cancer. de Marinis F, Pereira JR, Fossella F, Perry MC, Reck M, Salzberg M, Jassem J, Peterson P, Liepa AM, Moore P, Gralla RJ. Level: 2, State: Excluded.
Refid: 365 Phase III trial of carboplatin plus paclitaxel with or without gemcitabine in first-line treatment of epithelial ovarian cancer. du Bois A, Herrstedt J, Hardy-Bessard AC, Muller HH, Harter P, Kristensen G, Joly F, Huober J, Avall-Lundqvist E, Weber B, Kurzeder C, Jelic S, Pujade-Lauraine E, Burges A, Pfisterer J, Gropp M, Staehle A, Wimberger P, Jackisch C, Sehouli J. Level: 2, State: Excluded.
Refid: 412 Phase II trial of vinorelbine and oxaliplatin as first-line therapy in malignant pleural mesothelioma. Fennell DA, CSJP, Shamash J, Sheaff MT, Evans MT, Goonewardene TI, Nystrom ML, Gower NH, Rudd RM. Level: 2, State: Excluded.
Refid: 416 Phase III study of immediate compared with delayed docetaxel after front-line therapy with gemcitabine plus carboplatin in advanced non-small-cell lung cancer. Fidias PM, Dakhil SR, Lyss AP, Loesch DM, Waterhouse DM, Bromund JL, Chen R, Hristova-Kazmierski M, Treat J, Obasaju CK, Marciniak M, Gill J, Schiller JH. Level: 2, State: Excluded.
Refid: 449 Temozolomide in elderly patients with newly diagnosed glioblastoma and poor performance status: an ANOCEF phase II trial. Gallego Perez-Larraya J, Ducray F, Chinot O, Catry-Thomas I, Taillandier L, Guillamo JS, Campello C, Monjour A, Cartalat-Carel S, Barrie M, Huchet A, Beauchesne P, Matta M, Mokhtari K, Tanguy ML, Honnorat J, Delattre JY. Level: 2, State: Excluded.
Refid: 660 Phase II study of induction chemotherapy with TPF followed by radioimmunotherapy with Cetuximab and intensity-modulated radiotherapy (IMRT) in combination with a carbon ion boost for locally advanced tumours of the oro-, hypopharynx and larynx--TPF-C-HIT. Jensen AD, Krauss J, Potthoff K, Desta A, Habl G, Mavtratzas A, Windemuth-Kiesselbach C, Debus J, Munter MW. Level: 2, State: Excluded.
Refid: 682 Health-related quality of life impact of bevacizumab when combined with irinotecan, 5-fluorouracil, and leucovorin or 5-fluorouracil and leucovorin for metastatic colorectal cancer. Kabbinavar FF, Wallace JF, Holmgren E, Yi J, Cella D, Yost KJ, Hurwitz HI. Level: 2, State: Excluded.
Refid: 915 Paclitaxel plus bevacizumab versus paclitaxel alone for metastatic breast cancer. Miller K, Wang M, Gralow J, Dickler M, Cobleigh M, Perez EA, Shenkier T, Cella D, Davidson NE. Level: 2, State: Excluded.
Refid: 916 Randomized phase III trial of capecitabine compared with bevacizumab plus capecitabine in patients with previously treated metastatic breast cancer. Miller KD, Chap LI, Holmes FA, Cobleigh MA, Marcom PK, Fehrenbacher L, Dickler M, Overmoyer BA, Reimann JD, Sing AP, Langmuir V, Rugo HS. Level: 2, State: Excluded.
Refid: 947 Sunitinib versus interferon alfa in metastatic renal-cell carcinoma. Motzer RJ, Hutson TE, Tomczak P, Michaelson MD, Bukowski RM, Rixe O, Oudard S, Negrier S, Szczylik C, Kim ST, Chen I, Bycott PW, Baum CM, Figlin RA. Level: 2, State: Excluded.
Refid: 957 Randomized phase III trial of gemcitabine compared with pegylated liposomal doxorubicin in patients with platinum-resistant ovarian cancer. Mutch DG, Orlando M, Goss T, Teneriello MG, Gordon AN, McMeekin SD, Wang Y, Scribner DR Jr, Marciniack M, Naumann RW, Secord AA. Level: 2, State: Excluded.
Refid: 996 Health-related quality of life and colorectal cancer-specific symptoms in patients with chemotherapy-refractory metastatic disease treated with panitumumab. Odom D, Barber B, Bennett L, Peeters M, Zhao Z, Kaye J, Wolf M, Wiezorek J. Level: 2, State: Excluded.
Refid: 1044 Association of progression-free survival, overall survival, and patient-reported outcomes by skin toxicity and KRAS status in patients receiving panitumumab monotherapy. Peeters M, Siena S, Van Cutsem E, Sobrero A, Hendlisz A, Cascinu S, Kalofonos H, Devercelli G, Wolf M, Amado RG. Level: 2, State: Excluded.
Refid: 1046 Experience of external beam radiotherapy given adjuvantly or at relapse following surgery for craniopharyngioma. Pemberton LS, Dougal M, Magee B, Gattamaneni HR. Level: 2, State: Excluded.
Refid: 1060 Pfisterer J, Plante M, Vergote I, du Bois A, Hirte H, Lacave AJ, Wagner U, Stahle A, Stuart G, Kimmig R, Olbricht S, Le T, Emerich J, Kuhn W, Bentley J, Jackisch C, Luck HJ, Rochon J, Zimmermann AH, Eisenhauer E. Gemcitabine plus carboplatin compared with carboplatin in patients with platinum-sensitive recurrent ovarian cancer: an intergroup trial of the AGO-OVAR, the NCIC CTG, and the EORTC GCG. Level: 2, State: Excluded.
Refid: 1061 Combination therapy with gemcitabine and carboplatin in recurrent ovarian cancer. Pfisterer J, Vergote I, Du Bois A, Eisenhauer E. Level: 2, State: Excluded.
Refid: 1066 Carboplatin Plus Paclitaxel Versus Carboplatin Plus Pegylated Liposomal Doxorubicin As First-Line Treatment for Patients With Ovarian Cancer: The MITO-2 Randomized Phase III Trial. Pignata S, Scambia G, Ferrandina G, Savarese A, Sorio R, Breda E, Gebbia V, Musso P, Frigerio L, Del Medico P, Lombardi AV, Febbraro A, Scollo P, Ferro A, Tamberi S, Brandes A, Ravaioli A, Valerio MR, Aitini E, Natale D, Scaltriti L, Greggi S, Pisano C, Lorusso D, Salutari V, Legge F, Di Maio M, Morabito A, Gallo C, Perrone F. Level: 2, State: Excluded.
Refid: 1073 Health-related quality of life outcomes of docetaxel/carboplatin combination therapy vs. sequential therapy with docetaxel then carboplatin in patients with relapsed, platinum-sensitive ovarian cancer: results from a randomized clinical trial. Pokrzywinski R, Secord AA, Havrilesky LJ, Puls LE, Holloway RW, Lewandowski GS, Higgins RV, Nycum LR, Kohler MF, Revicki DA. Level: 2, State: Excluded.
Refid: 1129 Raltitrexed-eloxatin salvage chemotherapy in gemcitabine-resistant metastatic pancreatic cancer. Reni M, Pasetto L, Aprile G, Cordio S, Bonetto E, Dell’Oro S, Passoni P, Piemonti L, Fugazza C, Luppi G, Milandri C, Nicoletti R, Zerbi A, Balzano G, Di Carlo V, Brandes AA. Level: 2, State: Excluded.
Refid: 1198 Interferon-alpha as maintenance therapy in patients with multiple myeloma. Schaar CG, Kluin-Nelemans HC, Te Marvelde C, le Cessie S, Breed WP, Fibbe WE, van Deijk WA, Fickers MM, Roozendaal KJ, Wijermans PW. Level: 2, State: Excluded.
Refid: 1204 Outpatient taxol and carboplatin chemotherapy for suboptimally debulked epithelial carcinoma of the ovary results in improved quality of life: an Eastern Cooperative Oncology Group Phase II Study (E2E93). Schink JC, Weller E, Harris LS, Cella D, Gerstner J, Falkson C, Wadler S. Level: 2, State: Excluded.
Refid: 1288 Pazopanib in locally advanced or metastatic renal cell carcinoma: results of a randomized phase III trial. Sternberg CN, Davis ID, Mardiak J, Szczylik C, Lee E, Wagstaff J, Barrios CH, Salman P, Gladkov OA, Kavina A, Zarba JJ, Chen M, McCann L, Pandite L, Roychowdhury DF, Hawkins RE. Level: 2, State: Excluded.
Refid: 1307 Health-related quality of life as prognostic factor for response, progression-free survival, and survival in women with metastatic breast cancer. Svensson H, Hatschek T, Johansson H, Einbeigi Z, Brandberg Y. Level: 2, State: Excluded.
Refid: 1334 Capecitabine, bevacizumab, and mitomycin in first-line treatment of metastatic colorectal cancer: results of the Australasian Gastrointestinal Trials Group Randomized Phase III MAX Study. Tebbutt NC, Wilson K, Gebski VJ, Cummins MM, Zannino D, van Hazel GA, Robinson B, Broad A, Ganju V, Ackland SP, Forgeson G, Cunningham D, Saunders MP, Stockler MR, Chua Y, Zalcberg JR, Simes RJ, Price TJ. Level: 2, State: Excluded.
Refid: 1340 High-dose chronomodulated infusion of 5-fluorouracil (5-FU) and folinic acid (FA) (FF5-16) in advanced colorectal cancer patients. Terzoli E, Garufi C, Zappala AR, Vanni B, Pugliese P, Cappellini GA, Aschelter AM, Perrone M, Giannarelli D. Level: 2, State: Excluded.
Refid: 1349 Chemotherapy, bevacizumab, and cetuximab in metastatic colorectal cancer. Tol J, Koopman M, Cats A, Rodenburg CJ, Creemers GJM, Schrama JG, Erdkamp FLG, Vos AH, van Groeningen CJ, Sinnige HAM, Richel DJ, Voest EE, Dijkstra JR, Vink-Borger ME, Antonini NF, Mol L, van Krieken JMJH, Dalesio O, Punt CJA. Level: 2, State: Excluded.
Refid: 1383 Irinotecan versus infusional 5-fluorouracil: a phase III study in metastatic colorectal cancer following failure on first-line 5-fluorouracil. V302 Study Group. Van Cutsem E, Blijham GH. Level: 2, State: Excluded.
Refid: 1440 Comprehensive comparison of health-related quality of life after contemporary therapies for localized prostate cancer. Wei JT, Dunn RL, Sandler HM, McLaughlin PW, Montie JE, Litwin MS, Nyquist L, Sanda MG. Level: 2, State: Excluded.
Refid: 1445 Health-related quality of life during and after intraperitoneal versus intravenous chemotherapy for optimally debulked ovarian cancer: a Gynecologic Oncology Group Study. Wenzel LB, Huang HQ, Armstrong DK, Walker JL, Cella D. Level: 2, State: Excluded.
Refid: 1447 Erlotinib for advanced non-small-cell lung cancer in the elderly: an analysis of the National Cancer Institute of Canada Clinical Trials Group Study BR.21. Wheatley-Price P, Ding K, Seymour L, Clark GM, Shepherd FA. Level: 2, State: Excluded.
Refid: 1468 Impact of lapatinib plus trastuzumab versus single-agent lapatinib on quality of life of patients with trastuzumab-refractory HER2+ metastatic breast cancer. Wu Y, Amonkar MM, Sherrill BH, O’Shaughnessy J, Ellis C, Baselga J, Blackwell KL, Burstein HJ. Level: 2, State: Excluded.
Refid: 1495 A phase II study of temozolomide vs. procarbazine in patients with glioblastoma multiforme at first relapse. Yung WK, Albright RE, Olson J, Fredericks R, Fink K, Prados MD, Brada M, Spence A, Hohl RJ, Shapiro W, Glantz M, Greenberg H, Selker RG, Vick NA, Rampling R, Friedman H, Phillips P, Bruner J, Yue N, Osoba D, Zaknoen S, Levin VA. Level: 2, State: Excluded.
Refid: 1496 Multicenter phase II trial of temozolomide in patients with anaplastic astrocytoma or anaplastic oligoastrocytoma at first relapse. Temodal Brain Tumor Group. Yung WK, Prados MD, Yaya-Tur R, Rosenfeld SS, Brada M, Friedman HS, Albright R, Olson J, Chang SM, O’Neill AM, Friedman AH, Bruner J, Yue N, Dugan M, Zaknoen S, Levin VA. Level: 2, State: Excluded.
Refid: 1508 Symptom improvement in lung cancer patients treated with erlotinib: quality of life analysis of the National Cancer Institute of Canada Clinical Trials Group Study BR.21. Bezjak A, Tu D, Seymour L, Clark G, Trajkovic A, Zukin M, Ayoub J, Lago S, de Albuquerque Ribeiro R, Gerogianni A, Cyjon A, Noble J, Laberge F, Chan RT, Fenton D, von Pawel J, Reck M, Shepherd FA. Level: 2, State: Excluded.
Refid: 1688 Efficacy, safety and quality-of-life associated with lenalidomide plus dexamethasone for the treatment of relapsed or refractory multiple myeloma: the Spanish experience. Alegre A, Oriol-Rocafiguera A, Garcia-Larana J, Mateos MV, Sureda A, Chamorro CM, Cibeira MT, Aguado B, Knight R, Rosettani B. Level: 2, State: Excluded.
Refid: 1738 Efficacy and safety of maintenance erlotinib in Asian patients with advanced non-small-cell lung cancer: A subanalysis of the phase III, randomized SATURN study. Wu YL, Kim JH, Park K, Zaatar A, Klingelschmitt G, Ng C. Level: 2, State: Excluded.