# Relevance of Quality Assessment Items

Quality Criteria | Important to Drug Treatment Trials | Important in Studies Relating PFS to QoL | Unique to Trials Comparing PFS and QoL
Selection bias
Subjects in different groups recruited from same population | X | X
Subjects in different groups recruited over same time period | X | X
Inclusion/exclusion criteria clearly stated | X | X
Randomization used | X
Comparable baseline characteristics between groups | X
Apart from treatment under investigation, groups treated equally | X
Similarity between groups in potentially important confounders (e.g., those with and without PFS) or adequate adjustment for confounding | | | X
Patients are not censored at progression | | | X
Performance bias
PFS assessed in valid and reliable manner (central radiology review, RECIST criteria used, inter- and intra- observer variability reported) | X | X
Subjects and investigators blind to treatment group | X | X
Subjects awareness of PFS status is described | | | X
Attrition bias
Missing data addressed through description and analysis | X | X
Results unlikely to be affected by losses to follow-up | X | X
Missing data likely to be at random | X | X
Detection bias
Outcome (progression) assessors blind to treatment group | X | X
PFS and other endpoints defined | X | X
QOL administration process was described | X | X
A priori hypothesis regarding the relationship between PFS and QOL | | | X