# List of Drugs Approved Using Studies With a Primary Endpoint of PFS

Oncology drugs for advanced solid epithelial cancers approved by regulatory authorities using PFS as the primary endpoint (2005 to 2010)

Targeted Cancer | Drug | Approved (jurisdictions) | Stage | Type of Trial | Increase in OS
Breast cancer | Avastin (bevacizumab) | US, Europe, Canada | Metastatic | III | No
Breast cancer | Ixempra (Ixabepilone) | US, Canada | Metastatic or locally advanced | III | No
Breast cancer | Tykerb (Lapatinib ditosylalte) | US, Europe, Canada | Metastatic or locally advanced | III | No
Colorectal cancer | Avastin (bevacizumab) | US, Europe, Canada | Metastatic | III | No
Colorectal cancer | Vectibix (panitumumab) | US, Europe, Canada | Metastatic | III | No
Ovarian cancer | Doxil (Doxorubicin) | Europe, Canada | Metastatic | III | No
Ovarian cancer | Gemzar (gemcitabine) | US, Europe, Canada | Advanced | III | No
Ovarian Cancer | Yondelis (trabectedin) | Europe, Canada | Relapsed | III | No
Renal Cell Cancer | Nexavar (sorafenib) | US, Europe, Canada | Advanced | III | No
Renal Cell Cancer | Votrient (pazopanib) | US, Europe, Canada | Advanced, metastatic | III | No
Renal Cell Cancer | Sutent (sunitinib) | US, Europe, Canada | Advanced, metastic | III | No
NSCLC | Tarceva (erlotinib) | US, Europe, Canada | Metastatic, locally advanced | III | Yes
Squamous Cell Cancer of Head and Neck | Taxotere (docetaxel) | US, Europe, Canada | Inoperable, locally advanced | III | Yes