# Definitions of Additional Oncology Drug Endpoints

Disease-free survival (DFS): The time from random assignment to cancer recurrence or death from any cause.

Relapse-free survival (RFS): The time from treatment of disease to any event, irrespective of cause, except for any second primary cancers

Time to progression (TTP): The time from random assignment to disease progression. TTP does not include deaths, and these events are censored, either at the time of death or at an earlier visit.

Objective response rate (ORR): The proportion of subjects with a predefined amount of reduction in tumor burden as assessed on the basis of specific criteria such as the Response Evaluation Criteria in Solid Tumors (RECIST). Generally, ORR has been defined as the sum of partial responses plus complete responses (divided by total patients) and is considered a direct measure of drug antitumor activity.