# Technical Expert Panel

- David Clifford, Public Health and Government Affairs, PatientsLikeMe
- Terrie Cowley, Founder and President, TMJ Association
- Guy Eakin, Vice-President of Scientific Affairs, American Health Assistance Foundation
- Patricia Furlong, Founder and President, Parent Project Muscular Dystrophy and Duchene Connect patient registry
- Michael Manganiello, Founding Partner, HCM Strategists
- Richard Sharp, Director of Bioethics Research, Cleveland Clinic
- Sharon Terry, President and CEO, Genetic Alliance and Registries for All
- Suzanne D. Vernon, Scientific Director, CFIDS Association of America