# Resources

Two resources are available for organizations wishing to pursue PPRs. These include:

- Glicklich RE, Dreyer NA, eds. Registries for Evaluating Patient Outcomes: A User’s Guide. Second edition. AHRQ Publication No. 10-EHC049. Rockville, MD: Agency for Healthcare Research and Quality; 2010.
  While this guide was created for researchers and institutions creating researcher-generated patient registries, much of the process is valuable for disease advocacy organizations wishing to create a self-generated PPR. Organizations should note, however, the intended audience, and recognize that some information may need modification for PPRs.
- The Genetic Alliance Registry and BioBank (GARB) Toolbox serves as a map of tools and resources for those interested in starting or maintaining a registry and biobank or joining GARB. It aggregates resources from hundreds of credible sources. Individuals interested in starting a registry and biobank will find resources such as a start-up guide, strategic planning aids, and Institutional Review Board (IRB) guidance, available at http://biobank.org/toolbox/start_a_biobank. Webinars on topics such as marketing, governance, and new technologies are available for the more advanced registry and biobank manager. GARB also offers a monthly bulletin that contains the latest news about registries and biobanks, and hosts a listserv for those interested in discussing registries and biobanks.