# References

1 Getz K. The Gift of Participation: A Guide to Making Informed Decisions About Volunteering for a Clinical Trial. Bar Harbor, ME. Jerian Publishing. 2007.
2 Berger M, Dreyer N, Anderson F, et al. Prospective observational studies to assess comparative effectiveness: The IPSOR Good Research Practices Task Force Report. Value in Health. 2012;15:217-230. [pmid: 22433752].
3 Terry S, Horn E, Scott J, et al. Genetic Alliance Registry and Biobank: a novel disease advocacy-driven research solution. Personalized Medicine. 2011;8(2):207-13.
4 Terry S, Terry P, Rauen K, et al. Advocacy groups as research organizations: The PXE International Example. Nature Reviews Genetics. 2007;8(2):157-164.
5 Carman K, Dardess P, Maurer M, et al. Patient and family engagement: a framework for understanding the elements and developing interventions and policies. Health Affairs. 2013;32(2):223-31. [pmid: 23381514].
6 Gliklich R, Dreyer N. Registries for Evaluating Patient Outcomes: A User’s Guide. AHRQ Publication No. 10-EHC049. Rockville, MD. Agency for Healthcare Research and Quality. 2010.
7 Silveira P, Rodríguez C, Casati F, et al. On the Design of Compliance Governance Dashboards for Effective Compliance and Audit Management. Dan A, Gittler F, Toumani F, editors. Service-Oriented Computing. ICSOC/ServiceWave 2009 Workshops. Springer Berlin. Heidelberg. 2010;6275:208-17.
8 Rubinstein Y. Patient Registries. http://rarediseases.info.nih.gov/PatientRegistry.aspx. Accessed March 1, 2013.
9 Heger M. A registry of registries? The US backs the idea for patients. Nature Medicine. 2011;17(4). www.nature.com/nm/journal/v17/n1/full/nm0111-4a.html.
10 Gliklich R, Levy D, Karl J, et al. Registry of Patient Registries (RoPR): project overview. Rockville, MD. Agency for Healthcare Research and Quality. 2012.
11 Landy D, Brinich M, Colten M, et al. How disease advocacy organizations participate in clinical research: A survey of genetic organizations. Genetics in Medicine. 2012;14(2):223-8. [pmid: 22261756].
12 Colapinto J. Mother Courage: A family tragedy and a scientific crusade. The New Yorker. December. 20 and 27. 2010:64-75.
13 Social Networking and Online Health Communities: Identifying and Describing Patient-Generated Registries. 2012. http://srhrl.aaas.org/projects/personalized_med/registries/index.shtml.
14 Gerdes M. Why a registry? Real Life Practice Transformation: A Family Practice Management Blog. 2010. http://blogs.aafp.org/fpm/transformation/entry/why_a_registry. Accessed February 10, 2013.
15 Ortiz D. Using a simple patient registry to improve your chronic disease care. Family Practice Management. 2006;13(4):47-52. [pmid: 16671350].
16 O’Brien E. Patient registries and why they are essential for rare diseases. pharmaphorum. 2013. www.pharmaphorum.com/2013/02/21/patient-registries-rare-diseases-siren/. Accessed March 1, 2013.
17 Baggi F, Mantegazza R, Antozzi C, et al. Patient registries: Useful tools for clinical research in myasthenia gravis. Annals of the New York Academy of Sciences. 2012;1274(1):107-113. [pmid: 23252904].
18 Dreyer N, Garner S. Registries for robust evidence. JAMA. 2009;302(7):790-1. [pmid: 19690313].
19 Peterson P, Varosy P. Observational comparative effectiveness research: Comparative effectiveness and caveat emptor. Circulation: Cardiovascular Quality and Outcomes. 2012;2012(5):150-2. [pmid: 22438463].
20 Willke R, Mullins C. “Ten commandments” for conducting comparative effectiveness research using “real-world data”. J Manag Care Pharm. 2011;17(9 Suppl A):S10-15. [pmid: 22074669].
21 Frydman G. Patient-driven research: Rich opportunities and real risks. Journal of Participatory Medicine. 2009;1(1):e12.
22 Andrews L. Harnessing the benefits of biobanks. Journal of Law, Medicine, and Ethics. 2005;33:1-10.
23 Frost J, Okun S, Vaughan T, et al. Patient-reported outcomes as a source of evidence in off-label prescribing: Analysis of data from PatientsLikeMe. 2011;13(1):e6.
24 Ohno-Machado L, Meeker D, Kim K. Comprehensive inventory of research networks: Clinical data research networks, patient-powered research networks, and patient registries. Washington, DC. Patient-Centered Outcomes Research Institute. 2013.
25 Golosinski M. Health care and social networks: Creating an online patient community. Insead Knowledge: Healthcare. 2012. http://knowledge.insead.edu/csr/healthcare/health-care-and-social-networks-creating-an-online-patient-community-2341. Accessed January 10, 2013.
26 Hoffman J. Patients Like Me. New York Times. September. 30. 2008.
27 Frost J, Okun S, Vaughan T, et al. Patient-reported outcomes as a source of evidence in off-label prescribing: Analysis of Data From PatientsLikeMe. J Med Internet Res. 2011;13(1):e6. [pmid: 21252034].