# Pathways to Creating a Patient-Powered Registry or Network

The evolution of PPR and PPRN models and approaches is in its early stages and is changing rapidly. The initial decision of support and advocacy organizations to generate a PPR is now complicated by new opportunities. The two main pathways are:

1. Create an individual, stand-alone, single-condition PPR, using organizational resources and partnerships, or
2. Join an existing PPRN, using the preset infrastructure for a PPR that is connected to a variety of other registries.

Each option offers a set of trade-offs for the organization. Advocates of PPRNs note that existing PPRNs offer patient organizations many of the advantages of stand-alone PPRs but also provide greater efficiency and cost-effectiveness. Advocates for stand-alone PPRs believe that autonomy of decisionmaking is of greater value, and worry that an organization may be less visible within a larger collective. While the creation of a new PPRN is always possible, this option is the most costly and time-consuming, and requires existing partnerships with a variety of patient organizations, funders, research scientists, advisors, and other partners.

To simplify the choice, an organization may wish to consider the advantages and disadvantages of creating stand-alone PPR versus creating a PPR through a pre-existing PPRN. The advantages and disadvantages are discussed below; Table 1 provides an overview.

Table 1 Advantages and disadvantages of PPR models

Pathway | Advantages | Disadvantages
Create a stand-alone PPR | - More focus on what is important to affected individuals; - More control of design to meet needs; - More control of data, including use and sharing; - Potentially higher participation rates; - More opportunities to promote the organization | - Higher costs; - More resources needed for promotion; - Sole responsibility for data management and use
Join a PPRN | - Lower costs; - Greater promotion of the network across populations; - Reduced fracturing of patient sample; - Greater ability to do research across conditions or address concomitant conditions | - Less autonomy/control of design; - Less ownership of data; - Potentially less brand or name recognition^a^

Abbreviations: PPR = patient-powered registry; PPRN = patient-powered registry network.

a Some PPRNs allow member organizations to maintain their identity and brand, eliminating this disadvantage.

Advantages of creating a stand-alone registry
- More focus on what is important to affected individuals. Clearly, the autonomy that comes with a self-generated registry offers the most flexibility to collect data that are most relevant to the needs of patients and family members of the individual disease. Data collection can focus on specific research questions, and results can be reflected back to organizational members in ways that are most meaningful to their situation.
- More control of design. Organizations that create their own registries are able to control every aspect of the registry, from the type of information collected to the look and feel of the PPRN. The organization has complete freedom to innovate, developing and maintaining a registry that best meets the needs and interests of the organization and its constituency.
- More control of data. Organizations that create their own registries have more control over how the data are used in research, including the partnership model the organization wishes to employ with researchers, scientists, and other stakeholders. The stand-alone registry may have greater flexibility in designing the memorandum of understanding that governs data sharing with researchers.
- Higher participation rates. While high participation rates are not inherent in stand-alone registries, and several PPRs that live within a PPRN also show high rates of participation, there are several good reasons to assume higher rates through stand-alone PPRs. Stand-alone PPRs live firmly within their parent organization, and benefit from the trust and affinity to the organization as a key location for information, support, and involvement. Patients and/or family members are more likely to participate in the registry when they are able to connect it to a familiar host organization. Stand-alone PPRs can provide regular communications about what is happening with their data, and can incorporate the registry more directly into other aspects of the organization, utilizing a captive, well-connected audience to promote participation. Hybrid networks such as GARB also allow organizations to retain their brand and autonomy in order to enhance participation.
- More opportunities to promote the organization. Similarly, a stand-alone PPR is most likely to be directly associated with a disease advocacy organization (often by name, as was the case with PXE International)—a connection that facilitates the organization’s promotional efforts and adds to its value. Organizations are able to use their registry to promote other aspects of the organization easily, using the registry membership to cross-promote other important activities or initiatives. Stand-alone PPRs that are part of PPRNs which allow the organization to retain their individual identities may realize this benefit as well.

Disadvantages of creating a stand-alone registry
- Higher costs. Building a digital platform for a patient registry can be expensive—three to four hundred thousand dollars at a minimum. Creating a PPRN can be even more expensive and would require more resources for building collaborations with other PPRs. Annual costs of maintaining a PPR can vary, and are less likely to reflect the efficiencies of a shared infrastructure. Organizations must raise funds specifically for this purpose, and can wind up circumventing their autonomy in decisionmaking in an effort to solicit funders or partner organizations to pay for the generation or maintenance of the PPR.
- More resources are needed for promotion. Self-generated PPRs must rely on their parent organization to call attention to their registries and maintain active participation from members. Central to a registry’s success is its ability to attract patients and/or family members who will contribute information or samples. If multiple patient registries exist for a condition, then the organization may find itself competing for the attention of patients and researchers. The organization will need to set aside a larger amount of resources to promote the registry in order to ensure that it contains a robust representation of the population.
- Sole responsibility for data management and use. Stand-alone patient registries face sole responsibility for addressing the many issues that accompany self-reported and clinical data, from the reliability of the data to the protection of tissue samples in collection and storage. Expensive contracts with research repositories may be needed to ensure proper collection. Staff or external vendors may also be needed to translate data into information that can be shared with the network, such as aggregate summaries of experiences or treatment outcomes, or conclusions.

Advantages of joining a pre-existing PPRN
- Lower costs. Pre-existing networks and registries have already made the investment in technical infrastructure and design, saving patient organizations the high cost of these tasks. These PPRNs are not cost-free to patient organizations, however, and may have a set of fees associated with the addition of a condition population to the network, the inclusion of data in research projects, or fees for other aspects of inclusion. However, these networks are more able to create an economy of scale that provides cost savings for each participating PPR.
- Greater promotion across populations. Existing PPRNs attract new users in a variety of ways that often exceed the resources of an individual organization. Although each advocacy or support organization may need to supplement its own promotional efforts to ensure member engagement, the general promotion of the PPRN may assist greatly in the recruitment of individuals with a specific condition.
- Reduced fracturing of the patient sample. Having a large, multi-condition PPRN reduces the likelihood that a population with a specific condition will be split across several stand-alone registries, and thereby creates a more robust data set for research.
- Research across conditions/concomitant treatments. One potential advantage of multi-condition PPRNs is their ability to combine data from multiple conditions, so that researchers can study treatment effects or other shared experience across diseases. Another potential advantage of these combined condition data is the ability to analyze comorbidities and concomitant treatments, as these may be reflected in the aggregate data set.

Disadvantages of joining a pre-existing PPRN
- Less autonomy/control of design. Any advantage organizations may gain in financial savings may be offset by the loss of autonomy in registry design and data selection, although the degree of this disadvantage differs among PPRNs. Some PPRNs offer a standardized design and data collection template, and may not allow for significant modification. Although pre-existing networks all differ in their policies and approaches, autonomy to make independent decisions and policies may be limited, and will always involve negotiation with additional partners.
- Less ownership of data. Another important consideration surrounds the ownership of data, which may live with the PPRN rather than the individual organization joining the collaborative. While this may not be an issue and can be negotiated, organizations “joining” a pre-existing PPRN must realize that, as a participating organization, they may not have ownership of the data or samples their members provide and as a result may not have full discretion regarding their use.
- Less brand/name recognition. One common motivation to create a stand-alone PPR surrounds the ability to “name” a registry after an organization, connecting the PPR to the organization directly. This may be somewhat lost when a PPR is part of a larger PPRN, which tends to be recognized by the name of the PPRN and not by the individual organizations that have collaborated to create it. Some PPRNs, however, allow individual member organizations to maintain their identity and brand, which minimizes this effect.