# Emerging Issues

While PPRs and PPRNs remain at an early stage of evolution, several emerging issues will need study and resolution:

- Standardization of data collection. Both researcher-generated and patient-powered patient registries are moving toward standardization of data collection, ranging from the standardization of specific items to the standardization of entire survey instruments. Stand-alone PPRs, in their attempt to answer patient-relevant questions, may not have data that can be widely used outside those specific research questions, limiting interest from a range of researchers. Unlike clinical research institutions, PPRs lack access to certain standardized data collection points such as electronic medical records, although attempts are being made. PPRNs have standards for their own network, but no formal standardization across these networks has been established with the exception of a few that are using the NIH set of common data elements, which was established by multiple institutions. As these networks grow, the issue of standardization, particularly in contrast to traditional patient registries, will be important to resolve.
- Competition for patients and caregivers. Many experts believe that the addition of stand-alone PPRs increases the opportunity for additional fracturing of data collection efforts across the patient population. Multiple PPRs for both rare and chronic conditions can force competition for active engagement by patients who may choose between registries, thereby reducing the size of the data set, or who may participate in several registries at once, thereby increasing the challenge of aggregating data for the entire population.
- Quality of data. A final yet significant issue surrounds the acceptance and use of patient-reported data in the research community. While the publications generated from PPRs and PPRNs play an important role in changing current perceptions, patient-reported outcomes such as those sometimes collected in PPRNs are disregarded by some (though not all) in the academic and research community as biased, inconsistent, and unable to provide a sufficient basis for valid analysis. A deeper concern surrounds the use of online communities as the basis for PPRs or PPRNs, although some PPRs have correlated their data with medical records and found a high concordance. A 2011 article generated by data from PatientsLikeMe included this limitation:
  Finally, when collecting data from patients online, there is the distinct possibility of more egregious misrepresentation—namely, that users are not who they appear to be. Patients on the site could be falsifying their identities entirely. While this is always possible, certain Internet platforms may be at higher risk for these gross inaccuracies than others. In many websites built specifically to collect medication ratings from patients, users enter minimal information about themselves before entering treatment evaluations, thus lowering the barrier for misrepresentation. PatientsLikeMe, as a community based on ongoing interaction and a reputation built upon a time-based health profile, may be less susceptible to flagrant misrepresentation.27
  Organizations using PPRNs for research purposes with the intention of changing current clinical practice will need to continue to address this issue directly, working with researchers to assure the quality of the data collected and to promote the use of the data across the research community. For several PPRNs, clinical practice change has been accomplished through the use of the data collected by the network.