# Conclusion

Without question, patient-powered patient registries and networks are a rapidly evolving contributor to research, and particularly to research that focuses on direct improvements in practice. These entities blur traditional boundaries, breaking the barrier of patient, family, and advocate involvement and control in research, translation, and dissemination. A clear movement has emerged to connect individual patient organizations and single-condition patient registries into broader networks that unify, standardize, and optimize the data collection and research generation process. Yet, incentives remain for organizations that wish to pursue their own agendas and create independent single-condition patient registries for their constituencies, which may or may not be possible when joining a PPRN.

A number of factors in the current health care environment may influence further evolution of patient-powered research, including the increased attention and interest in patient-centered research evidence, the expanding role of patients in institutional research efforts, and new technological advancements that enable new forms of patient outreach and engagement. It is likely that the options and choices for patient advocacy and support organizations wishing to contribute to research will expand. Yet, it is also likely that best practices and standards will emerge that guide both researcher-powered and patient-powered registries and research networks, providing additional knowledge to organizations seeking the most efficient and effective approaches to generating knowledge about conditions and treatments.