# About This Paper

This white paper is part of a series of reports, information projects, and activities for the Community Forum, an effort to improve and expand public and stakeholder engagement in research supported by the Agency for Healthcare Research and Quality’s (AHRQ) Effective Health Care Program. Funded initially under the American Recovery and Reinvestment Act (ARRA), Community Forum activities seek to:

- Build on existing efforts to involve stakeholders—clinicians, patients, caregivers, health services researchers, health care payers, and others—having a specific interest in AHRQ’s EHC Program research.
- Advance the science for obtaining input from both stakeholders and the general public in the development and dissemination of health care research.

A series of key informant interviews was conducted from October through December of 2012. Key informants were identified as those working with patient-powered registries as creators, administrators, or researchers. From these calls, a Technical Expert Panel was assembled. The Technical Expert Panel included individuals recommended by key informants who represented a broad range of perspectives and experiences with PPRs. The panel reviewed a preliminary outline of this paper, provided additional information and insight toward its content, and reviewed a draft of this paper.