# Results

## Eligible Systematic Reviews

Our searches yielded a total of 20,871 citations; after screening of titles and abstracts 1199 citations were considered potentially eligible and were retrieved in full text. An additional 26 publications were identified through perusal of reference lists of other review articles, for a total of 1225 papers reviewed in full text. Of those, 465 were excluded after full text review and 760 were considered eligible.^b^ Figure 1 presents the search strategy flow. The list of included studies is presented in Appendix C; a summary of reasons for exclusion of studies reviewed in full text is presented in Appendix D. In the following sections we present a summary of the total database along with an assessment for trends over time for items of interest. Appendix E presents the regression results for trends over time for all factors assessed, both over the whole period covered (1987–2009), and for the subgroup of studies published in recent years (2005–2009); Appendix E also includes a comparison between studies published before 2003 versus those published from 2003 onwards.

b One publication25 was a reprint of a previously published manuscript 26; both were retained in the database.

Figure 1 Literature search flow

Flow of the literature search and study selection process for this review. A list of included studies is provided in Appendix C and a list of reasons for exclusion is provided in Appendix D.

Figure 1 presents the flow of the literature search and study selection process for this review. The figure demonstrates that of 20,871 citations, 1199 were considered potentially eligible and were retrieved in full text. An additional 26 citations identified through perusal of reference lists were also reviewed in full text. In total, 465 papers were excluded (a list of reasons for exclusion is provided in Appendix D) and 760 were included in the review (a list of included studies is provided in Appendix C).

Studies were published over more than 20 years (from 1987 to 2009), and there was a clear trend in increased number of reviews over time (P for trend < 0.001; Figure 2).

Figure 2 Number of meta-analyses of test accuracy published per year

Line plot of the number of test accuracy meta-analyses included in this overview by year of publication.

Figure 2 is a line plot of the number of test accuracy meta-analyses included in this overview by year of publication (1987 to 2009). The number of publications has been increasing over time and the rate of increase appears to have accelerated in recent years. The last 2 years included in the graph (2008 and 2009) have the highest number of published meta-analyses over the whole study period.

Meta-analyses had synthesized evidence from a median of 18 studies (per review), but the number of studies included varied substantially (25^th^–75^th^ percentile = 11–30; minimum-maximum = 2–351). Most reviews examined imaging tests (44 percent) or molecular biomarkers (28 percent). Most tests pertained to diagnosis or prediction in oncology (25 percent), cardiology (21 percent), gastrointestinal disease (16 percent), obstetrics and gynecology (15 percent), and infectious disease (13 percent). A majority (52 percent) of meta-analyses considered a single index test and 82 percent considered a single reference standard (Table 1). Figure 3 depicts the distribution of the number of studies included in the eligible systematic reviews. Comparative analyses of two or more index tests were reported in 132 reviews (17 percent).

Table 1 Characteristics of eligible reviews

Characteristic | N [25^th^–75^th^ percentile] (min–max) | N (%)
Topic: Oncology | | 188 (25)
Topic: Cardiovascular disease | | 160 (21)
Topic: Gastrointestinal | | 119 (16)
Topic: Obstetrics and gynecology | | 114 (15)
Topic: Infectious disease | | 98 (13)
Topic: Pulmonary medicine | | 68 (9)
Topic: Orthopedics | | 44 (6)
Topic: Nephrology and urology | | 38 (5)
Topic: Neurology | | 37 (5)
Topic: Pediatrics | | 29 (4)
Topic: Psychiatry | | 22 (3)
Topic: Ear-nose-throat | | 19 (3)
Topic: Rheumatology | | 8 (1)
Test type: Imaging | | 336 (44)
Test type: Biomarker | | 211 (28)
Test type: Clinical exam | | 112 (15)
Test type: Histology, cytology, or culture | | 103 (14)
Test type: Physiologic test | | 40 (5)
Test type: Challenge/stress test | | 31 (4)
Test type: Endoscopic examinations | | 21 (3)
Index test: Per review, median | 1 [1–3] (1–56)
Reviews with a single index test | | 396 (52)
Reviews with 2 index tests | | 157 (21)
Reviews with 3 index tests | | 68 (9)
Reviews with 4 index tests | | 43 (6)
Reviews with ≥5 index tests | | 96 (13)
Reference standard tests per review, median | 1 [1–1] (1–7)
Reviews with a single reference standard test | | 625 (82)
Reviews with 2 reference standard tests | | 74 (10)
Reviews with 3 reference standard tests | | 38 (5)
Reviews with 4 reference standard tests | | 14 (2)
Reviews with ≥5 reference standard tests | | 9 (1)
Included studies: Per review, median | 18 [11–30] (2–351)
Reviews with 2–10 studies | | 180 (24)
Reviews with 11–20 studies | | 246 (32)
Reviews with 21–30 studies | | 151 (20)
Reviews with 31–40 studies | | 63 (8)
Reviews with 41–50 studies | | 45 (6)
Reviews with ≥51 studies | | 75 (10)
Publications 1985–1989 | | 5 (<1)
Publications 1990–1994 | | 22 (3)
Publications 1995–1999 | | 95 (13)
Publications 2000–2004 | | 201 (26)
Publications 2005–2009 | | 437 (58)

max = maximum; min = minimum.

“Clinical exam” denotes the assessment of aspects of the clinical examination as diagnostic tests; “challenge/stress test” denotes tests such as the glucose challenge test for diabetes, or stress tests (pharmacological or activity-based). The percentages of medical topics and test types do not sum up to 100% because many test uses could be classified under multiple topics and some reviews assessed more than one test types.

Figure 3 Number of primary studies included in each meta-analysis of test accuracy

Histogram of the number of primary studies included in each meta-analysis of test accuracy included in this overview. Bin width was set at 5 studies.

Figure 3 is a histogram of the number of primary studies included in each meta-analysis of test accuracy included in this overview. Bin width was set at 5 studies. The figure demonstrates that the vast majority of reviews have included less than 100 studies. The mode (bin with highest frequency) of the distribution was at “5-10 studies” (the mode of the distribution corresponded to approximately 150 reviews).

Over time, there was no statistically significant change in the number of studies included in each review (-1 percent per year; 95 percent CI -2, 0.3; P = 0.147), or the number of reference standards considered (0 percent per year; 95 percent CI -0.6, 0.7; P = 0.902). However, there has been a small reduction in the number of index tests assessed (-1.2 percent per year; 95 percent CI -2.4, 0; P = 0.040). The proportion of reviews reporting comparative analyses of at least two index tests has not changed over time (per year odds ratio, OR = 0.98; 95 percent CI 0.94, 1.02; P = 0.292).

Over time there was an increase in meta-analyses pertaining to gastrointestinal disease (per year OR = 1.07; 95 percent CI 1.02, 1.13; P = 0.008), oncology (per year OR = 1.05; 95 percent CI 1.01, 1.09; P = 0.020), orthopedics (per year OR = 1.09; 95 percent CI 1.00, 1.19; P = 0.041) and pulmonary medicine (per year OR = 1.10; 95 percent CI 1.03, 1.18; P = 0.005). Changes over time were non-significant for other clinical topics (Figure 4). There was also a borderline increase in the proportion of meta-analyses assessing clinical challenge tests (per year OR = 1.11; 95 percent CI 1.00, 1.23; P = 0.046) (Figure 5).

Figure 4 Trends over time in the proportion of meta-analyses, by clinical field

Line plot of the annual proportion of meta-analyses of test accuracy in various clinical fields.

CVD = cardiovascular disease; OBGYN = obstetrics and gynecology; GI = gastrointestinal disease; ID = infectious disease; ONC = oncology; NEPH & UROL = nephrology and urology; RHEUM = rheumatology; PULM = pulmonary medicine; ORTH = orthopedics; PSYCH = psychiatry; ENT = ear-nose-throat; NEUR = neurology; PEDS = pediatrics. Results are shown only after 1995 because the number of meta-analyses in previous years was too small and proportions were unstable.

Figure 4 presents a matrix of line plots of the annual proportion of meta-analyses of test accuracy in various clinical fields (cardiovascular disease; obstetrics and gynecology; gastrointestinal disease; infectious disease; oncology; nephrology and urology; rheumatology; pulmonary medicine; orthopedics; psychiatry; ear-nose-throat; neurology; pediatrics). The most prominent increase over time has been observed for studies in oncology although an increasing trend was also observed for meta-analyses of gastrointestinal disease and pulmonary medicine. Results were shown only after 1995 because the number of meta-analyses in previous years was too small and proportions were unstable.

Figure 5 Trends over time in the proportion of meta-analyses, by test category

Line plot of the annual proportion of meta-analyses of test accuracy in various test categories.

Hist/Cyto/Culture = histological, cytological, or culture-based tests; clinical challenge = clinical challenge tests

Results are shown only after 1995 because the number of meta-analyses in previous years was too small and proportions were unstable.

Figure 5 presents a matrix of line plots of the annual proportion of meta-analyses of test accuracy in various test categories (histological, cytological, or culture-based tests; clinical examination; imaging tests; biomarkers; clinical challenge tests; physiologic tests; endoscopies). There was no appreciable trend over time for any of these test categories. Results were shown only after 1995 because the number of meta-analyses in previous years was too small and proportions were unstable.

## Literature Review Methods in Reviews of Test Accuracy

Most reviews reported searching multiple electronic databases. MEDLINE searches were nearly universal (96 percent of all reviews) and 62 percent of the reviews reported searching at least one electronic databases in addition to MEDLINE. Searches of Embase (47 percent) and the Cochrane Library (30 percent) were also common. References lists of eligible studies and relevant review articles were also considered in a large proportion of the reviews (76 percent and 28 percent, respectively). On the contrary, contacting experts in the field (17 percent) and obtaining unpublished information (12 percent) were less common.

To guide the selection of eligible studies, 19 percent of eligible reviews reported using quality criteria and 21 percent reported using a minimum cut-off sample size. These cut-offs were generally low (median = 10 participants), but some reviews excluded studies of even moderate sample size (25^th^–75^th^ percentile = 10–20; 99^th^ percentile = 100). Reviews often considered only studies published in English (36 percent); however, 31 percent of reviews explicitly reported not imposing any language restrictions.

Table 2 summarizes information on the databases searched, the reporting of search strategies in the eligible reviews, and the study selection characteristics of eligible reviews.

Table 2 Literature search and study selection methods employed in reviews of test accuracy

Characteristic | Number [25^th^–75^th^ percentile] (min–max) | Number (%)
Availability of the search strategy: Reporting of the exact search string | | 195 (26)
Availability of the search strategy: Reporting of search terms | | 445 (59)
Availability of the search strategy: Search strategy available upon request | | 43 (6)
Availability of the search strategy: No information reported | | 77 (10)
Reporting of the years searched | | 697 (92)
Exclusion of studies based on quality | | 146 (19)
Exclusion of studies based on sample size | | 159 (21)
Median sample size cut-off | 10 [10–20] (4–1000)
English-only (or other single language) | | 271 (36)
English and other specific languages | | 90 (12)
No language restrictions | | 235 (31)
No information on selection based on language | | 164 (22)
Database: MEDLINE | | 729 (96)
Database: Embase | | 358 (47)
Database: Cochrane library | | 228 (30)
Database: CINAHL | | 82 (11)
Database: ISI WOK/ SCI | | 74 (10)
Database: Current Contents | | 35 (5)
Database: Other specific database | | 202 (27)
Source of eligible studies: Conference proceedings | | 88 (12)
Source of eligible studies: Bibliographies of eligible articles | | 576 (76)
Source of eligible studies: Bibliographies of relevant review articles | | 213 (28)
Source of eligible studies: Experts in relevant fields | | 132 (17)
Source of eligible studies: Manual/electronic searches of specific journals | | 105 (14)
Source of eligible studies: Source of eligible studies: Manufacturers of tests/assays | | 33 (4)
Source of eligible studies: Unpublished information | | 93 (12)

CINAHL = Cumulative Index to Nursing and Allied Health Literature; ISI WOK/ SCI = Institute of Scientific Information Web of Knowledge/Science Citation Index; max = maximum; min = minimum

Unless stated otherwise, the total sample size for analyses in this table is 744. A single review considering only Korean-language articles is included here along with the “English-only” reviews, to indicate the consideration of articles in a single language only. Percentages may not sum to 100 percent due to rounding.

Figure 6 presents trends over time in the reporting of search strategies and methods for study selection for inclusion in meta-analysis. Over time there has been a substantial increase in the number of reviews reporting the exact search strategy used (per year OR = 1.09; 95 percent CI 1.05, 1.14; P < 0.001) and the years searched (per year OR = 1.08; 95 percent CI 1.02, 1.13; P = 0.004). However, there has also been an increase in the number of reviews using quality criteria to select studies for inclusion (per year OR = 1.06; 95 percent CI 1.02, 1.11; P = 0.007).

Figure 6 Trends over time in the reporting of search strategies and study selection criteria

Line plots of the annual proportion of meta-analyses of test accuracy using specific reporting practices for their search strategies or study selection criteria.

Exact search = reporting of the search strategy in a way that can be directly replicated; Search terms = reporting of search terms without the full search strategy or Boolean operands; Search on demand = the full search strategy is available from the authors or in a website (other than that of the journal publishing the meta-analysis); years searched = reporting of the years covered by the searches; quality exclusion = exclusion of studies from the meta-analysis based on quality criteria; size exclusion = exclusion of studies from the meta-analysis based on sample size criteria.

Results are shown only after 1995 because the number of meta-analyses in previous years was too small and proportions were unstable.

Figure 6 presents a matrix of line plots of the annual proportion of meta-analyses of test accuracy using specific methods or reporting practices for their search strategies or study selection criteria. Trends in the following practices or reporting items are show: reporting of the search strategy in a way that can be directly replicated; reporting of search terms without the full search strategy or Boolean operands; the full search strategy is available from the authors or in a website (other than that of the journal publishing the meta-analysis); reporting of the years covered by the searches; exclusion of studies from the meta-analysis based on quality criteria; exclusion of studies from the meta-analysis based on sample size criteria. There appears to have been an increasing trend in recent years (since 2002) in the number of meta-analyses reporting the exact search strategy used. The number of meta-analyses reporting search terms only appears to have declined over time. Almost all meta-analyses have reported the years searched (and this has changed little over time). Results were shown only after 1995 because the number of meta-analyses in previous years was too small and proportions were unstable.

Figure 7 presents trends over time in the use of electronic databases and other literature sources by systematic reviews of test accuracy. Overall, there was an increasing trend in the use of electronic databases other than MEDLINE (per year OR = 1.30; 95 percent CI 1.24, 1.35; P < 0.001); this appeared to be due to the increasing use of Embase (per year OR = 1.28; 95 percent CI 1.23, 1.35; P < 0.001); the Cochrane libraries (per year OR = 1.30; 95 percent CI 1.23, 1.38; P < 0.001); the Science Citation Index (or other ISI databases, per year OR = 1.18; 95 percent CI 1.09, 1.28; P < 0.001); CINAHL (per year OR = 1.25; 95 percent CI 1.15, 1.36; P < 0.001); or other specific electronic databases (per year OR = 1.25; 95 percent CI 1.18, 1.32; P < 0.001).

Figure 7 Trends over time in the proportion of meta-analyses using specific databases or other sources to identify eligible studies

Line plots of the annual proportion of meta-analyses of test accuracy using specific databases or other sources to identify eligible studies. Results are shown only after 1995 because the number of meta-analyses in previous years was too small and proportions were unstable.

Bibliographies = perusal of reference lists of included studies; CC = current contents; CINAHL = Cumulative Index to Nursing and Allied Health Literature; Cochrane = searching of databases maintained by the Cochrane Collaboration; Experts in the field consulted to provide additional studies; Handsearching = searching manually (or electronically) the contents of selected journals; Other specific = searching of other specific electronic databases; Reviews = perusal of the reference lists of relevant review articles; SCI = Science Citation Index or other Institute of Scientific Information databases; Unpublished = search for studies not published in the peer-reviewed literature.

Figure 7 presents a matrix of line plots of the annual proportion of meta-analyses of test accuracy using specific databases or other sources to identify eligible studies. Separate graphs were shown for the following potential sources of studies: the MEDLINE database; the Embase database; any of the Cochrane Libraries; the Cumulative Index to Nursing and Allied Health Literature database; the Science Citation Index or other Institute of Scientific Information databases; the Current Contents database; other specific electronic databases; conference proceedings; reference lists of included articles; reference lists of relevant review articles; contact with experts in the field; hand searching of the databases of specific journals; websites or databases of test manufacturers; unpublished studies. Results were shown only after 1995 because the number of meta-analyses in previous years was too small and proportions were unstable. Over time there have been increases in the number of meta-analyses using Embase, the Cochrane Libraries, the Institute of Scientific Information databases and CINAHL. MEDLINE has been used by almost all meta-analyses (and its use has remained relatively constant over time).

Figure 8 presents trends over time in the handling of languages other than English in reviews of test accuracy. There has been an increase in the proportion of studies that explicitly reported considering non-English language articles (considering studies published in at least one language other than English, per year OR = 1.05; 95 percent CI 1.02, 1.09; P = 0.003). This increase is mostly due to an increasing number of reviews not imposing any language restrictions. As expected, there has been a concomitant decrease in reviews considering English language studies only (per year OR = 0.96; 95 percent CI 0.93, 0.99; P = 0.028).

Figure 8 Trends over time in the proportion of studies searching for or considering for inclusion studies based on language of publication criteria

Stacked bar graph of the annual proportion of meta-analyses of test accuracy using different language criteria to identify eligible studies.

Single language = reviews only considering studies published in a single language (in all but one case the language used was English, a single review considered only studies published in Korean); English+ = reviews considering studies published in English and at least one more specific Language; No restrictions = reviews not using language restrictions to select eligible studies; Not reported = studies not providing information on the languages considered.

Results are shown only after 1990 because the number of meta-analyses in previous years was too small and proportions were unstable.

Figure 8 is a stacked bar graph of the annual proportion of meta-analyses of test accuracy using different language criteria to identify eligible studies. The graph demonstrates, for each 5-year period between 1990 and 2009 (1990-94; 1995-99; 2000-04 and 2005-09), the proportion of meta-analyses considering only a single language (in all but one review the single language considered was English; 1 meta-analysis considered only Korean publications); the proportion of meta-analyses including studies published in English and at least one more specific language; the proportion of meta-analyses imposing no language restrictions; and the proportion of meta-analyses that did not report the languages considered. Results were shown only after 1990 because the number of meta-analyses in previous years was too small and proportions were unstable. Over time, the proportions of meta-analyses considering only studies published in a single language and those not reporting the languages considered have declined. In contrast, the proportions of meta-analyses imposing no restrictions and those considering at least one other language in addition to English have increased.

## Factors Affecting the Number of Studies Included in Each Review

The number of studies included in each meta-analysis did not appear to be affected by the search of electronic databases in addition to MEDLINE (0.2 percent difference between reviews that included at least one additional electronic database; 95 percent CI -12.7, 12.1 percent; P = 0.967) or the inclusion of languages other than English (8.3 percent more studies in reviews including non-English language studies; 95 percent CI -2.7, 21 percent; P = 0.139), after adjusting for publication year, clinical topic, and test category.

## Quality Assessment and Use of Checklists

The majority of reviews performed some quality assessment of the studies they included. This assessment was based on the QUADAS checklist in 20 percent (27 percent after 2004) of reviews. Nine percent (12 percent after 2003) of reviews reported using the STARD guideline to develop items for quality assessment of the primary studies they included. Commonly assessed items included blinding (65 percent), prospective recruitment of patients (59 percent), verification bias (48 percent), and the description of the reference standard used (88 percent). Blinding of test assessors was examined in more detail for articles published since 2004: blinding of the index test assessor to the reference standard results was reported in 53 percent, and blinding of the reference standard assessor to the index test results in 50 percent of the 500 studies published between 2004 and 2009 (Table 3).

Table 3 Quality assessment in systematic reviews of medical test accuracy studies

Characteristic | Studies, n (%)
Settings of test use | 295 (39)
Recruitment of consecutive patients | 322 (42)
Prospective/retrospective design | 446 (59)
Exact description of the reference standard | 667 (88)
Expertise of the test readers | 116 (15)
Any blinding (all eligible studies) | 496 (65)
Blinding assessors of the index test to the reference standard (500 studies published since 2004) | 265 (53)
Blinding assessors of the reference standard test to the index test (500 studies published since 2004) | 250 (50)
Blinding unspecified (500 studies published since 2004) | 74 (15)
No blinding (500 studies published since 2004) | 141 (28)
Demographic characteristics of participants: Age | 361 (48)
Demographic characteristics of participants: Sex (500 studies published since 2004) | 269 (54)
Location of studies | 190 (25)
Spectrum bias (500 studies published since 2004) | 262 (52)
Selection bias (500 studies published since 2004) | 291 (58)
Time between the performance of the index and reference standard tests (500 studies published since 2004) | 201 (40)
Test independence (500 studies published since 2004) | 190 (38)
Indeterminate results (500 studies published since 2004) | 175 (35)
Withdrawals (500 studies published since 2004) | 167 (33)
Verification bias | 367 (48)
Quality assessment based on the QUADAS tool | 148 (19)
Quality assessment based on use of items from the STARD reporting guideline | 65 (9)

QUADAS = Quality Assessment of Diagnostic Accuracy Studies; STARD = Standards for Reporting of Diagnostic Accuracy.

Over time, assessment of specific quality items has generally increased. (Figure 9). For example, there has been an increase in the number of reviews appraising verification bias (per year OR = 1.17; 95 percent CI 1.13, 1.22; P < 0.001); spectrum bias (per year OR = 1.16; 95 percent CI 1.04, 1.29; P = 0.007); test assessor blinding (per year OR = 1.09; 95 percent CI 1.05, 1.13; P < 0.001); whether study design was prospective (per year OR = 1.12; 95 percent CI 1.09, 1.16; P < 0.001); and whether patients were recruited consecutively (per year OR = 1.07; 95 percent CI 1.04, 1.11; P < 0.001).

Figure 9 Trends over time in the proportion of meta-analyses of test accuracy appraising specific quality items or using quality assessment checklists

Line plot of the annual proportion of meta-analyses of test accuracy appraising selected quality items among the primary studies they included. Information for the following variables was only collected for studies published 2004 onwards: Blinding (index), Blinding (reference), Spectrum bias, Sex, Selection bias, Indeterminate test results, and Withdrawals. The QUADAS tool and the STARD checklist were published in November 2003 and January 2003, respectively. Results for all variables are shown only after 1995 because the number of meta-analyses in previous years was too small and proportions were unstable.

Consecutive = reviews assessing whether the primary studies enrolled patients consecutively; Prospective = reviews assessing whether the primary studies had a prospective design; Blinding = any assessment of blinding in the primary studies; Blinding (index) = assessment of whether the index test assessor was blinded to the reference standard results; Blinding (reference) = assessment of whether the reference standard assessor was blinded to the index test results; Age = reviews that extracted information on participant age from the primary studies; Sex = reviews that extracted information on participant sex from the primary studies; Location = reviews that extracted information on primary study locations; Selection = reviews that extracted information on the selection criteria of the primary studies; Indeterminate = reviews that examined the handling of indeterminate test results in the primary studies; Withdrawals = reviews that examined the handling of withdrawals in the primary studies; QUADAS = Quality Assessment of Diagnostic Accuracy Studies; STARD = Standards for Reporting of Diagnostic Accuracy.

Line plot of the annual proportion of meta-analyses of test accuracy appraising selected quality items among the primary studies they included. Line plots were presented for the following practices or reporting items: the proportion of reviews assessing whether the primary studies enrolled patients consecutively; the proportion of reviews assessing whether the primary studies had a prospective design; the proportion of reviews performing any assessment of blinding in the primary studies; the proportion of reviews performing any assessment of whether the index test assessor was blinded to the reference standard results; the proportion of reviews performing any assessment of whether the reference standard assessor was blinded to the index test results; the proportion of reviews that extracted information on participant age from the primary studies; the proportion of reviews that extracted information on participant sex from the primary studies; the proportion of reviews that extracted information on primary study locations; the proportion of reviews that extracted information on the selection criteria of the primary studies; the proportion of reviews that examined the handling of indeterminate test results in the primary studies; the proportion of reviews that examined the handling of withdrawals in the primary studies; the proportion of reviews basing their quality assessment on the Quality Assessment of Diagnostic Accuracy Studies tool; and the proportion of reviews basing their quality assessment on the Standards for Reporting of Diagnostic Accuracy guidelines. Information for the following variables was only collected for studies published 2004 onwards: Blinding (index), Blinding (reference), Spectrum bias, Sex, Selection bias, Indeterminate test results, and Withdrawals. The QUADAS tool and the STARD checklist were published in November 2003 and January 2003, respectively. Results for all other variables were shown after 1995 because the number of meta-analyses in previous years was too small and proportions were unstable. Overall the proportion of reviews assessing these quality items has increased over time. The most impressive increases were seen in the assessment of indeterminate results, withdrawals, blinding and prospective study design. The slope of the increase in the proportion of studies using the QUADAS instrument was very steep, suggesting the rapid diffusion of the use of the tool in recent years.

These improvements in recent years in the quality assessment of primary studies have been associated with the increasing use of checklists of items relevant to study quality (Table 4): since 2004, the QUADAS tool has increasingly been used to guide quality assessment (per year OR = 1.62; 95 percent CI 1.41, 1.86; P < 0.001). Similarly, since 2003, the STARD reporting guideline has also been increasingly (but not quite statistically significantly) used to develop items for the quality assessment of primary studies of test accuracy (per year OR = 1.15; 95 percent CI 0.99, 1.33; P = 0.059).

Table 4 Use of QUADAS or STARD to guide quality assessment in reviews of medical tests (2004–2009)

Year | % of reviews using QUADAS | % of reviews using STARD
2004 | 1.6 | 9.5
2005 | 13.3 | 12.0
2006 | 20.9 | 13.4
2007 | 39.6 | 13.2
2008 | 41.1 | 15.9
2009 | 44.3 | 12.4

QUADAS = Quality Assessment of Diagnostic Accuracy Studies; STARD = Standards for Reporting of Diagnostic Accuracy

## Statistical Analyses and Presentation of Results in Reviews of Test Accuracy

The most popular test accuracy metrics used in meta-analysis were sensitivity (77 percent) and specificity (74 percent). Diagnostic odds ratios (34 percent) and likelihood ratios (31 percent) were also commonly used (Table 5). Quantitative results were often presented in forest plots (39 percent) or ROC curves (53 percent); other graphical displays were uncommon. Heterogeneity tests were performed in 58 percent of the available studies; potential causes of underlying heterogeneity were explored in 57 percent of analyses (33 percent using exclusively subgroup analyses exclusively and 24 percent using meta-regression with or without subgroup analyses). The most commonly used heterogeneity metrics were Cochran's Q statistic, Fisher's exact test, and the I^2^ index. Random effects models were used in the majority (57 percent) of the studies.

Table 5 Statistical analyses and presentation of results in reviews of test accuracy

Characteristics | Studies, n (%)
Use of random effects models | 436 (57)
Metrics used in quantitative analyses: Sensitivity | 582 (77)
Metrics used in quantitative analyses: Specificity | 560 (74)
Metrics used in quantitative analyses: OR | 257 (34)
Metrics used in quantitative analyses: Likelihood ratios | 236 (31)
Metrics used in quantitative analyses: Predictive values | 97 (13)
Metrics used in quantitative analyses: Accuracy | 42 (6)
Metrics used in quantitative analyses: AUC | 40 (5)
Metrics used in quantitative analyses: Q* | 26 (3)
Display of synthesis results: Forest plots | 300 (39)
Display of synthesis results: ROC curves | 403 (53)
Heterogeneity testing | 439 (58)
Exploration of heterogeneity: Meta-regression analyses (+/- subgroup analyses) | 180 (24)
Exploration of heterogeneity: Subgroup analyses only | 247 (33)
No exploration of heterogeneity | 333 (44)
Statistical analyses: Univariate meta-analysis | 660 (87)
Statistical analyses: ROC-based methods (including sROC and hsROC) | 379 (50)
Statistical analyses: Advanced statistical methods – BREM/hsROC | 70 (9)
Statistical analyses: Other advanced models | 11 (1)
sROC model (only among studies using ROC analyses): Moses-Littenberg | 326 (86)
sROC model (only among studies using ROC analyses): Rutter-Gatsonis | 24 (6)
sROC model (only among studies using ROC analyses): Other | 29 (7)
Comparative analyses of index tests | 132 (17)
Direct comparative analyses of index tests (only among the 131 studies reporting on test comparisons) | 33 (25)
Indirect comparative analyses of index tests (only among the 131 studies reporting on test comparisons) | 98 (75)
Bayesian statistical analyses | 17 (2)
Reporting of data to replicate analyses: Counts reported or can be calculated | 448 (59)
Reporting of data to replicate analyses: Data not available | 312 (41)

AUC = area under the curve; BREM = bivariate random effects meta-analysis; OR = diagnostic/predictive odds ratio; HsROC = hierarchical summary receiver operating characteristic; ROC = receiver operating characteristic; sROC = summary receiver operating characteristic

Statistical analyses most often used univariate (one outcome at a time) meta-analyses (87 percent) and the fixed effects summary receiver operating curve characteristics method as described by Moses and Littenberg13,27 (86 percent of the studies performing ROC analyses). More theoretically motivated methods, such as bivariate random effects6,28 or hierarchical summary ROC curve models9,10, were rarely used (11 percent), although this is changing (see below for time trend).

Figure 10 presents trends over time in the proportion of studies using specific metrics for meta-analysis of test accuracy information. Over time there has been increasing use of the diagnostic OR (per year OR = 1.17; 95 percent CI 1.12, 1.22; P < 0.001), sensitivity (per year OR = 1.07; 95 percent CI 1.03, 1.11; P < 0.001), specificity (per year OR = 1.08; 95 percent CI 1.04, 1.12; P < 0.001), and likelihood ratios (per year OR = 1.13; 95 percent CI 1.08, 1.18; P < 0.001), as metrics for meta-analyses of test accuracy.

Figure 10 Trends over time in the proportion of meta-analyses using each metric of test accuracy

Line plot of the annual proportion of meta-analyses of test accuracy using each metric for quantitative evidence synthesis. OR = odds ratio; LR = likelihood ratio; AUC = area under the receiver operating characteristic curve; Q* = point where sensitivity equals specificity on SROC curve). Results are shown only after 1995 because the number of meta-analyses in previous years was too small and proportions were unstable.

Figure 10 presents a matrix of line plots of the annual proportion of meta-analyses of test accuracy using each metric for quantitative evidence synthesis. Lines are plotted for the following metrics: sensitivity; specificity; odds ratio; likelihood ratios; predictive values; accuracy; area under the receiver operating characteristic curve; and the point where sensitivity equals specificity on SROC curve (Q-star). Results are shown only after 1995 because the number of meta-analyses in previous years was too small and proportions were unstable. Over time there have been increases in the use of sensitivity, specificity, the odds ratio and likelihood rations. Sensitivity and specificity are the most commonly used metrics in recent years. Predictive values, accuracy, the area under the receiver operating characteristic curve and Q-star are generally not used often and the proportion of reviews utilizing these metrics has changed little in recent years.

Figure 11 presents trends over time in the proportion of reviews assessing, accounting for, and exploring heterogeneity. There has been a clear increase in the number of studies assessing heterogeneity using statistical tests (per year OR = 1.21; 95 percent CI 1.17, 1.26; P < 0.001), and exploring the underlying reasons leading to heterogeneity using subgroup or meta-regression methods (per year OR = 1.08; 95 percent CI 1.04, 1.12; P < 0.001). This increase has been mostly due to the use of subgroup analyses, as the proportion of reviews performing meta-regression analyses has not changed significantly over time; per year OR = 1.03 (95 percent CI 0.95, 1.11; P = 0.484). Use of random effects models also increased over time (per year OR = 1.21; 95 percent CI 1.16, 1.26; P < 0.001).

Figure 11 Trends over time in the proportion of meta-analyses assessing, accounting for in the analyses and exploring heterogeneity

Line plot of the annual proportion of meta-analyses of test accuracy using tests for heterogeneity, employing random effects meta-analysis models, exploring heterogeneity (using subgroup or regression analyses), and using meta-regression analyses. Results are shown only after 1995 because the number of meta-analyses in previous years was too small and proportions were unstable.

Figure 11 presents a matrix of line plots of the annual proportion of meta-analyses of test accuracy using tests for heterogeneity, employing random effects meta-analysis models, exploring heterogeneity (using subgroup or regression analyses), and using meta-regression analyses. Results were shown only after 1995 because the number of meta-analyses in previous years was too small and proportions were unstable. There have been impressive increases over time in the proportion of reviews performing heterogeneity tests, and using random effects models. The proportion of reviews performing subgroup or meta-regression analyses has also increased over time, however this appears to have been mostly due to the increase in subgroup analyses (because the proportion of reviews performing meta-regression analyses has remained relatively low and stable over time).

Figure 12 presents trends in the proportion of studies using advanced statistical methods (for comparison a trend line for studies using the Moses-Littenberg method is also presented). Overall, the proportion of studies using advanced meta-analysis methods has increased over time (per year OR = 1.27; 95 percent CI 1.16, 1.39; P < 0.001). Specifically, the bivariate random effects meta-analysis model and the hierarchical sROC model are increasingly used: per year OR = 1.42; 95 percent CI 1.26, 1.60; P < 0.001) (Table 6). These methods were used about 20 percent of the time in 2008 and 2009 following publication of several articles that recommended their use.6,28-30 Bayesian statistical methods have been rarely utilized.

Figure 12 Trends over time in the proportion of meta-analyses using advanced statistical methods for quantitative evidence synthesis

Line plot of the annual proportion of meta-analyses of test accuracy using advanced meta-analysis methods, such as the bivariate random effects meta-analysis or the hierarchical summary receiver operating characteristic curve models; other advanced methods (in most cases, random effects variants of the Moses-Littenberg sROC method); or Bayesian analysis methods. Results are shown only for years after 1995 because the statistical methods of interest were practically not used at all during earlier years and the number of meta-analyses was relatively small leading to instability of the estimated annual proportions. The plot for meta-analyses using the Moses-Littenberg method is presented for comparison, BREM = bivariate random effects meta-analysis; hsROC = hierarchical receiver operating characteristic curve; sROC = summary receiver operating characteristic method.

Figure 12 presents a matrix of line plots of the annual proportion of meta-analyses of test accuracy using advanced meta-analysis methods, such as the bivariate random effects meta-analysis or the hierarchical summary receiver operating characteristic curve models; other advanced methods (in most cases, random effects variants of the Moses-Littenberg sROC method); or Bayesian analysis methods. For comparison a fourth line plot depicts the temporal changes in the proportion of reviews using the fixed effects Moses-Littenberg method. Results were shown only for years after 1995 because the statistical methods of interest were practically not used at all during earlier years and the number of meta-analyses was relatively small leading to instability of the estimated annual proportions. There has been a clear increase in the proportion of reviews using the bivariate random effects meta-analysis or the hierarchical summary receiver operating characteristic curve model (from almost 0 to more than 20% per year). Other advanced meta-analysis methods and Bayesian methods have rarely been used (both proportions have never exceeded 10%); the low rate of use has remained fairly constant over time. Use of the fixed effects Moses-Littenberg method appears to have declined in recent years.

Table 6 Use of advanced statistical methods in reviews of medical tests (2000-09)

Year | % of Reviews Using BREM/hsROC
2000 | 0.0
2001 | 0.0
2002 | 0.0
2003 | 7.9
2004 | 7.9
2005 | 5.3
2006 | 4.5
2007 | 12.1
2008 | 22.4
2009 | 19.6

BREM = bivariate random effects meta-analysis; hsROC = hierarchical receiver operating characteristic curve

## Comparison of Reviews in the Five Most Commonly Assessed Medical Fields

The five most commonly assessed medical fields in meta-analyses of test accuracy were oncology (25 percent), cardiovascular disease (21 percent), gastrointestinal disease (16 percent), obstetrics and gynecology (15 percent), and infectious disease (13 percent). For the comparison between fields we excluded 92 studies (16 percent of those relevant to the top 5 fields) that were considered relevant to more than one of these fields. There were few differences in the methods or reporting of meta-analyses in these fields (Tables 7a and 7b). There was a higher rate of exclusion of studies using quality criteria in meta-analyses in gastrointestinal (28 percent) and cardiovascular (25 percent) disease compared to those in obstetrics and gynecology (12 percent), infectious disease (13 percent), or oncology (17 percent); overall P = 0.022. Additionally, there was a higher rate of exclusion of studies based on sample size cut-offs in reviews in oncology (31 percent), cardiovascular disease (26 percent), and infectious disease (23 percent), compared to those in obstetrics and gynecology (9 percent) or gastrointestinal disease (17 percent); overall P = 0.003. Due to the large number of comparisons performed these differences may be chance findings.

Table 7a Comparison of meta-analyses of test accuracy conducted in the five medical fields where most reviews had been published: number of studies, tests, and reference standards

Characteristics | Cardiovascular Disease (n=156) | Obstetrics & Gynecology (n=77) | Gastrointestinal Disease (n=65) | Infectious Disease (n=77) | Oncology (n=120) | P-value
Number of studies, median [25^th^–75^th^ percentile] | 20 [12–40] | 16 [10–24] | 17 [9–29] | 19 [11–32] | 18 [11–30] | 0.099
Number of index tests, median [25^th^–75^th^ percentile] | 2 [1–3] | 1 [1–2] | 2 [1–3] | 1 [1–2] | 1 [1–2] | 0.047
Number of reference standards, median [25^th^–75^th^ percentile] | 1 [1–1] | 1 [1–2] | 1 [1–1] | 1 [1–1] | 1 [1–1] | 0.006

Table 7b Comparison of meta-analyses of test accuracy conducted in the five medical fields where most reviews had been published

Characteristics | Cardiovascular Disease (n=156) n (%) | Obstetrics & Gynecology (n=77) n (%) | Gastrointestinal Disease (n=65) n (%) | Infectious Disease (n=77) n (%) | Oncology (n=120) n (%) | P-value
Searching and study selection: Exact search provided | 46 (29) | 17 (22) | 17 (26) | 19 (25) | 25 (21) | 0.540
Searching and study selection: Years searched | 147 (94) | 73 (95) | 60 (92) | 70 (91) | 112 (93) | 0.843
Searching and study selection: Exclusion based on quality criteria | 39 (25) | 9 (12) | 18 (28) | 10 (13) | 20 (17) | 0.022
Searching and study selection: Exclusion based on minimum sample size | 40 (26) | 7 (9) | 11 (17) | 18 (23) | 37 (31) | 0.003
Searching and study selection: MEDLINE plus at least one additional database | 66 (42) | 42 (55) | 36 (55) | 45 (58) | 55 (46) | 0.091
Quality assessment: Settings | 63 (40) | 21 (27) | 23 (35) | 34 (44) | 43 (36) | 0.220
Quality assessment: Consecutive patients | 63 (40) | 41 (53) | 24 (37) | 39 (51) | 44 (37) | 0.077
Quality assessment: Prospective patient sampling | 80 (51) | 54 (70) | 39 (60) | 45 (58) | 70 (58) | 0.103
Quality assessment: Any blinding | 106 (68) | 43 (56) | 39 (60) | 60 (78) | 77 (64) | 0.040
Quality assessment: Verification bias | 70 (45) | 38 (49) | 29 (45) | 37 (48) | 60 (50) | 0.902
Quality assessment: QUADAS | 30 (19) | 8 (10) | 15 (23) | 21 (27) | 21 (18) | 0.086
Quality assessment: STARD | 13 (8) | 7 (9) | 6 (9) | 7 (9) | 11 (9) | 0.996
Provides data for re-analysis | 92 (59) | 50 (65) | 37 (57) | 44 (57) | 79 (66) | 0.576
Heterogeneity testing | 84 (54) | 51 (66) | 39 (60) | 42 (55) | 61 (51) | 0.253
Random effects methods | 96 (62) | 44 (57) | 39 (60) | 39 (51) | 61 (52) | 0.385
Advanced methods | 17 (11) | 7 (9) | 7 (11) | 5 (6) | 14 (12) | 0.809

QUADAS = Quality Assessment of Diagnostic Accuracy Studies; STARD = Standards for Reporting of Diagnostic Accuracy

P-values are from Fisher exact tests for nominal variables and Kruskal-Wallis tests for continuous or count variables. Studies investigating tests belonging to different categories have been excluded. Meta-analyses that included index tests belonging to more than one category have been excluded from this analysis.

## Comparison of Reviews of the Five Most Commonly Assessed Test Categories

The five most commonly assessed test categories were imaging tests (44 percent), biomarkers (28 percent), aspects of the clinical examination (15 percent), histological tests (14 percent, including cytological and culture-based tests), and physiologic/challenge (5 percent) tests. For the comparison between test types we excluded 75 studies (11 percent of those relevant to the top 5 test categories) that considered tests belonging to more than one test type (for example, reviews of multiple index tests belonging to different categories). There were several significant differences in the reporting and methods characteristics of meta-analyses assessing different test types (Tables 8a and 8b). The most striking of these differences pertained to the methods used by the reviews to appraise the quality of primary studies. Generally reviews of histological, cytological or culture based tests were less likely to assess quality items such as assessor blinding, verification bias, and prospective or consecutive patient recruitment. The use of the QUADAS instrument to guide quality assessment was also less common in reviews of histological, cytological or culture based tests. Similar patterns were observed for physiologic tests (although the number of available reviews was substantially smaller).

Table 8a Comparison of meta-analyses of test accuracy conducted in the five test categories assessed in most meta-analyses: number of studies, tests, and reference standards

Characteristics | Histological Tests (n=68) | Clinical Examination(n= 81) | Imaging Tests (n=296) | Biomarkers (n=172) | Physiologic Tests^*^ (n=22) | P-value
Number of studies, median [25th–75th percentile] | 19 [11–28] | 14 [10–24] | 19 [12–33] | 21 [11–35] | 11 [8–27] | 0.010
Number of index tests, median [25th–75th percentile] | 1 [1–2] | 2 [1–4] | 1 [1–2] | 1 [1–2] | 1 [1–1] | 0.001
Number of reference standards, median | 1 [1–1] | 1 [1–1] | 1 [1–1] | 1 [1–1] | 1 [1–1] | 0.869

* Including challenge tests.

Table 8b Comparison of meta-analyses of test accuracy conducted in the five test categories assessed in most meta-analyses

Characteristics | Histological Tests^*^ (n=68) n (%) | Clinical Examination (n=81) n (%) | Imaging Tests (n=296) n (%) | Biomarkers (n=172) n (%) | Physiologic Tests^†^ (n=22) n (%) | P-value
Searching and study selection: Exact search provided, | 14 (21) | 31 (38) | 71 (24) | 42 (24) | 5 (23) | 0.096
Years searched, n (%) | 58 (85) | 77 (95) | 274 (93) | 160 (93) | 19 (86) | 0.161
Searching and study selection: Exclusion based on quality criteria, n (%) | 9 (13) | 17 (21) | 53 (18) | 39 (23) | 1 (5) | 0.171
Searching and study selection: Exclusion based on minimum sample size, n (%) | 10 (15) | 9 (11) | 93 (31) | 25 (15) | 6 (27) | <0.001
Searching and study selection: MEDLINE plus at least one additional database, n (%) | 26 (38) | 45 (56) | 145 (49) | 96 (56) | 7 (32) | 0.039
Quality assessment: Settings, n (%) | 14 (21) | 55 (68) | 79 (27) | 83 (48) | 11 (50) | <0.001
Quality assessment: Consecutive patients, n (%) | 24 (35) | 36 (44) | 121 (41) | 85 (49) | 4 (18) | 0.030
Quality assessment: Prospective patient sampling, n (%) | 32 (47) | 44 (54) | 193 (65) | 104 (60) | 8 (36) | 0.007
Quality assessment: Any blinding, n (%) | 29 (43) | 58 (72) | 202 (68) | 117 (68) | 14 (64) | 0.001
Verification bias, n (%) | 22 (32) | 40 (49) | 152 (51) | 93 (54) | 5 (23) | 0.003
QUADAS, n (%) | 4 (6) | 14 (17) | 66 (22) | 45 (26) | 1 (5) | 0.001
STARD, n (%) | 2 (3) | 3 (4) | 27 (9) | 23 (13) | 1 (5) | 0.034
Provides data for re-analysis | 47 (69) | 42 (52) | 177 (60) | 101 (59) | 13 (59) | 0.325
Heterogeneity testing | 31 (46) | 44 (54) | 184 (62) | 110 (64) | 10 (458) | 0.034
Random effects methods | 33 (49) | 49 (60) | 168 (57) | 109 (63) | 9 (41) | 0.112
Advanced methods | 3 (4) | 8 (10) | 38 (13) | 15 (9) | 2 (9) | 0.280

QUADAS = Quality Assessment of Diagnostic Accuracy Studies; STARD = Standards for Reporting of Diagnostic Accuracy

P-values are from Fisher exact tests for nominal variables and Kruskal-Wallis tests for continuous or count variables. Studies investigating tests belonging to different categories have been excluded. Meta-analyses covered more than one of the relevant clinical topics have been excluded from this analysis.

* Including cytological and culture-based tests.

† Including challenge tests.

## Journal Impact Factor and Citation Count

In regression analyses with citation count (of each meta-analysis) as the dependent variable, after adjusting for the effect of journal impact factor and accounting for the number of years since manuscript publication, the following factors were predictive of a higher number of citations (with P<0.001): whether the study did not evaluate aspects of the clinical examination (“not clinical exam”); a larger number of included studies; whether the meta-analysis was relevant to adult medicine (“not pediatrics”); whether results were presented graphically; whether advanced meta-analysis methods were used; whether the topic was not related to orthopedics; and whether comparisons between alternative index tests were reported.

In analyses assessing the association between journal impact factor and reporting characteristics of systematic reviews of test accuracy, higher journal impact factor was associated with the following characteristics (with P<0.001): assessing the accuracy of aspects of the clinical examination; reporting quantitative analyses using likelihood ratio metrics; use of random effects methods; availability of the full search strategy upon request; assessment of blinding in the primary studies; whether the review assessed the enrollment of consecutive patients in the primary studies; and whether the reference lists of relevant review articles were perused as part of the search strategy.

When comparing reviews published in high impact factor general medical journals versus reviews published in other journals, few reporting differences were observed (with P<0.001): high-impact factor journals were more likely to publish meta-analyses assessing the accuracy of aspects of the clinical examination and using random effects models.

We note that the above analyses are exploratory in nature, and may—to a large extent—reflect journal editorial policies. Appendix Tables F1–F3 present additional information from the analyses of citation counts and journal impact factors.