# References

1 Miettinen OS. The modern scientific physician: 3. Scientific diagnosis. CMAJ. 2001;165:781-82. [pmid: 11584568].
2 Lijmer JG, Leeflang M, Bossuyt PM. Proposals for a phased evaluation of medical tests. Med Decis Making. 2009;29:E13-E21. [pmid: 19605881].
3 Lord SJ, Irwig L, Simes RJ. When is measuring sensitivity and specificity sufficient to evaluate a diagnostic test, and when do we need randomized trials?. Ann Intern Med. 2006;144:850-5. [pmid: 16754927].
4 Hayen A, Macaskill P, Irwig L, et al. Appropriate statistical methods are required to assess diagnostic tests for replacement, add-on, and triage. J Clin Epidemiol. 2010;63:883-91. [pmid: 20079607].
5 Gatsonis C, Paliwal P. Meta-analysis of diagnostic and screening test accuracy evaluations: methodologic primer. AJR Am J Roentgenol. 2006;187:271-81. [pmid: 16861527].
6 Reitsma JB, Glas AS, Rutjes AW, et al. Bivariate analysis of sensitivity and specificity produces informative summary measures in diagnostic reviews. J Clin Epidemiol. 2005;58:982-90. [pmid: 16168343].
7 van Houwelingen HC, Zwinderman KH, Stijnen T. A bivariate approach to meta-analysis. Stat Med. 1993;12:2273-84. [pmid: 7907813].
8 van Houwelingen HC, Arends LR, Stijnen T. Advanced methods in meta-analysis: multivariate approach and meta-regression. Stat Med. 2002;21:589-624. [pmid: 11836738].
9 Rutter CM, Gatsonis CA. Regression methods for meta-analysis of diagnostic test data. Acad Radiol. Suppl 1. 1995;2:S48-S56. [pmid: 9419705].
10 Rutter CM, Gatsonis CA. A hierarchical regression approach to meta-analysis of diagnostic test accuracy evaluations. Stat Med. 2001;20:2865-84. [pmid: 11568945].
11 Willis BH, Quigley M. Uptake of newer methodological developments and the deployment of meta-analysis in diagnostic test research: a systematic review. BMC Med Res Methodol. 2011;11:27. [pmid: 21401947].
12 Glas AS, Lijmer JG, Prins MH, et al. The diagnostic odds ratio: a single indicator of test performance. J Clin Epidemiol. 2003;56:1129-35. [pmid: 14615004].
13 Moses LE, Shapiro D, Littenberg B. Combining independent studies of a diagnostic test into a summary ROC curve: data-analytic approaches and some additional considerations. Stat Med. 1993;12:1293-316. [pmid: 8210827].
14 Reid MC, Lachs MS, Feinstein AR. Use of methodological standards in diagnostic test research. Getting better but still not good. JAMA. 1995;274:645-51. [pmid: 7637146].
15 Ransohoff DF, Feinstein AR. Problems of spectrum and bias in evaluating the efficacy of diagnostic tests. N Engl J Med. 1978;299:926-30. [pmid: 692598].
16 Lijmer JG, Mol BW, Heisterkamp S, et al. Empirical evidence of design-related bias in studies of diagnostic tests. JAMA. 1999;282:1061-6. [pmid: 10493205].
17 Rutjes AW, Reitsma JB, Di NM, et al. Evidence of bias and variation in diagnostic accuracy studies. CMAJ. 2006;174:469-76. [pmid: 16477057].
18 Westwood ME, Whiting PF, Kleijnen J. How does study quality affect the results of a diagnostic meta-analysis?. BMC Med Res Methodol. 2005;5:20. [pmid: 15943861].
19 Whiting P, Rutjes AW, Reitsma JB, et al. The development of QUADAS: a tool for the quality assessment of studies of diagnostic accuracy included in systematic reviews. BMC Med Res Methodol. 2003;3:25. [pmid: 14606960].
20 Whiting P, Rutjes AW, Dinnes J, et al. Development and validation of methods for assessing the quality of diagnostic accuracy studies. Health Technol Assess. 1. 2004;8(25):iii-234.
21 Whiting PF, Weswood ME, Rutjes AW, et al. Evaluation of QUADAS, a tool for the quality assessment of diagnostic accuracy studies. BMC Med Res Methodol. 2006;6:9. [pmid: 16519814].
22 Bossuyt PM, Reitsma JB, Bruns DE, et al. Towards complete and accurate reporting of studies of diagnostic accuracy: The STARD Initiative. Ann Intern Med. 2003;138:40-4. [pmid: 12513043].
23 Bossuyt PM, Reitsma JB, Bruns DE, et al. The STARD statement for reporting studies of diagnostic accuracy: explanation and elaboration. Ann Intern Med. 2003;138:W1-12. [pmid: 12513067].
24 Irwig L, Macaskill P, Glasziou P, et al. Meta-analytic methods for diagnostic test accuracy. J Clin Epidemiol. 1995;48:119-30. [pmid: 7853038].
25 Steingart KR, Henry M, Laal S, et al. A systematic review of commercial serological antibody detection tests for the diagnosis of extrapulmonary tuberculosis. Postgrad Med J. 2007;83:705-12. [pmid: 17989270].
26 Steingart KR, Henry M, Laal S, et al. A systematic review of commercial serological antibody detection tests for the diagnosis of extrapulmonary tuberculosis. Thorax. 2007;62:911-8. [pmid: 17675320].
27 Littenberg B, Moses LE. Estimating diagnostic accuracy from multiple conflicting reports: a new meta-analytic method. Med Decis Making. 1993;13:313-21. [pmid: 8246704].
28 Chu H, Cole SR. Bivariate meta-analysis of sensitivity and specificity with sparse data: a generalized linear mixed model approach. J Clin Epidemiol. 2006;59:1331-2. [pmid: 17098577].
29 Harbord RM, Deeks JJ, Egger M, et al. A unification of models for meta-analysis of diagnostic accuracy studies. Biostatistics. 2007;8:239-51. [pmid: 16698768].
30 Arends LR, Hamza TH, van Houwelingen JC, et al. Bivariate random effects meta-analysis of ROC curves. Med Decis Making. 2008;28:621-38. [pmid: 18591542].
31 Mallett S, Deeks JJ, Halligan S, et al. Systematic reviews of diagnostic tests in cancer: review of methods and reporting. BMJ. 2006;333:413. [pmid: 16849365].
32 Irwig L, Tosteson AN, Gatsonis C, et al. Guidelines for meta-analyses evaluating diagnostic tests. Ann Intern Med. 1994;120:667-76. [pmid: 8135452].
33 Whiting P, Rutjes AW, Dinnes J, et al. A systematic review finds that diagnostic reviews fail to incorporate quality despite available tools. J Clin Epidemiol. 2005;58:1-12. [pmid: 15649665].
34 Dinnes J, Deeks J, Kirby J, et al. A methodological review of how heterogeneity has been examined in systematic reviews of diagnostic test accuracy. Health Technol Assess. 2005;9:1-113. iii.
35 Moher D, Tetzlaff J, Tricco AC, et al. Epidemiology and reporting characteristics of systematic reviews. PLoS Med. 2007;4:e78. [pmid: 17388659].
36 Wen J, Ren Y, Wang L, et al. The reporting quality of meta-analyses improves: a random sampling study. J Clin Epidemiol. 2008;61:770-5. [pmid: 18411041].
37 Moher D, Schulz KF, Altman DG. The CONSORT statement: revised recommendations for improving the quality of reports of parallel-group randomized trials. Ann Intern Med. 2001;134:657-62. [pmid: 11304106].
38 Altman DG, Schulz KF, Moher D, et al. The revised CONSORT statement for reporting randomized trials: explanation and elaboration. Ann Intern Med. 2001;134:663-94. [pmid: 11304107].
39 Moher D, Jones A, Lepage L. Use of the CONSORT statement and quality of reports of randomized trials: a comparative before-and-after evaluation. JAMA. 2001;285:1992-5. [pmid: 11308436].
40 Plint AC, Moher D, Morrison A, et al. Does the CONSORT checklist improve the quality of reports of randomised controlled trials? A systematic review. Med J Aust. 2006;185:263-7. [pmid: 16948622].
41 Harbord RM. metandi: Meta-analysis of diagnostic accuracy using hierarchical logistic regression. Sterne J, editor. Meta-analysis: an updated collection from the Stata Journal. Stata Press. 2011.
42 Macaskill P. Empirical Bayes estimates generated in a hierarchical summary ROC analysis agreed closely with those of a full Bayesian analysis. J Clin Epidemiol. 2004;57:925-32. [pmid: 15504635].
43 Chappell FM, Raab GM, Wardlaw JM. When are summary ROC curves appropriate for diagnostic meta-analyses?. Stat Med. 2009;28:2653-68. [pmid: 19591118].
44 Wilczynski NL, Haynes RB. Consistency and accuracy of indexing systematic review articles and meta-analyses in medline. Health Info Libr J. 2009;26:203-10. [pmid: 19712212].
45 Berlin JA, Santanna J, Schmid CH, et al. Individual patient- versus group-level data meta-regressions for the investigation of treatment effect modifiers: ecological bias rears its ugly head. Stat Med. 2002;21:371-87. [pmid: 11813224].
46 Fowler PB. Evidence-based diagnosis. J Eval Clin Pract. 1997;3:153-9. [pmid: 9276592].
47 Whiting P, Harbord R, de Salis I, et al. Evidence-based diagnosis. J Health Serv Res Policy. Suppl 3. 2008;13:57-63. [pmid: 18806193].
48 Pandharipande PV, Gazelle GS. Comparative effectiveness research: what it means for radiology. Radiology. 2009;253:600-5. [pmid: 19952024].
49 Hayen A, Macaskill P, Irwig L, et al. Appropriate statistical methods are required to assess diagnostic tests for replacement, add-on, and triage. J Clin Epidemiol. 2010;63:883-91. [pmid: 20079607].
50 Tatsioni A, Zarin DA, Aronson N, et al. Challenges in systematic reviews of diagnostic technologies. Ann Intern Med. 2005;142:1048-55. [pmid: 15968029].
51 Irwig L, Tosteson AN, Gatsonis C, et al. Guidelines for meta-analyses evaluating diagnostic tests. Ann Intern Med. 1994;120:667-76. [pmid: 8135452].
52 Deville WL, Buntinx F, Bouter LM, et al. Conducting systematic reviews of diagnostic studies: didactic guidelines. BMC Med Res Methodol. 2002;2:9. [pmid: 12097142].
53 Deeks JJ. Systematic reviews in health care: Systematic reviews of evaluations of diagnostic and screening tests. BMJ. 2001;323:157-62. [pmid: 11463691].
54 Lijmer JG, Bossuyt PM. Various randomized designs can be used to evaluate medical tests. J Clin Epidemiol. 2009;62:364-73. [pmid: 18945590].
55 Lord SJ, Irwig L, Simes RJ. When is measuring sensitivity and specificity sufficient to evaluate a diagnostic test, and when do we need randomized trials?. Ann Intern Med. 2006;144:850-5. [pmid: 16754927].
56 Fineberg HV, Bauman R, Sosman M. Computerized cranial tomography. Effect on diagnostic and therapeutic plans. JAMA. 1977;238:224-7. [pmid: 406427].
57 Trikalinos TA, Siebert U, Lau J. Decision-analytic modeling to evaluate benefits and harms of medical tests: uses and limitations. Med Decis Making. 2009;29:E22-9. [pmid: 19734441].