# Discussion

We performed a comprehensive review of 760 medical test accuracy meta-analyses published over the last 25 years. This work provides a “snapshot” of the available literature and an overview of longitudinal trends in methods and reporting, with the aim of identifying where future reviews could be improved. Meta-analyses of test accuracy are increasingly being pursued: in recent years approximately 100 such reports have been published annually. Overall, the available literature appears to have several limitations (Box 1): most reviews do not appraise important quality items, statistical analyses use methods that may be suboptimal for test accuracy and direct comparisons of index tests are scarce. Our findings regarding the limitations of existing systematic reviews of test accuracy generally agree with previously published, smaller-scale surveys of reviews of test accuracy. We have summarized some of these previous empirical investigations in Table 9. Generally, previous assessments of systematic reviews of diagnostic tests have assessed much smaller numbers of studies or have been limited to a single clinical topic (e.g., oncology31). Furthermore, with the exception of a report focusing on the statistical methods used for meta-analysis,11 no previous overview has included an adequate number of studies spread over several years that would allow the exploration of trends over time.

Box 1 Common limitations of existing systematic reviews of test accuracy

- Comparative effectiveness of medical tests
  - Most systematic reviews were focused on a single index test.
  - Most meta-analyses did not consider (direct or indirect) comparisons between alternative index tests.
- Literature search and study identification
  - Many systematic reviews relied on a relatively limited number of databases for the identification of potentially eligible studies.
  - Search strategies were often not provided in detail.
  - Selection of studies
    - Selection of studies for inclusion in meta-analyses was frequently based on quality criteria. It was often unclear whether these criteria were predetermined in a review protocol.
- Data-extraction and qualitative synthesis
  - Many reviews did not provide adequate summaries of the included studies. Settings of test use, the expected role of the test, study design characteristics, and demographics of participants, were often not reported.
  - The counts needed to reconstruct the 2×2 tables of results used in each study were often not provided.
- Assessment of study quality
  - The assessment of study quality was often limited. Validated checklists, such as the QUADAS, were not universally used.
  - Quality assessment methods were non-standardized and operational definitions for individual quality items were not always explicitly provided.
- Meta-analysis
  - Assessment of statistical heterogeneity was often not performed or was incompletely reported.
  - Regression methods were infrequently used to explore between-study heterogeneity.
  - A substantial number of published reviews did not use random effects meta-analysis models; thus, summary estimates may not be generalizable to future studies.
  - Advanced meta-analysis methods that account for the bivariate nature of sensitivity and specificity were infrequently used, even in recent years.

Table 9 Summary of selected previously published overviews of systematic review of test accuracy

Characteristics | Irwig, 1994^32^ | Whiting, 2005^33^ | Dinnes, 2005^34^ | Mallet, 2006^31^ | Moher, 2007^35^ | Willis, 2011^11^ | Current Project
Number of included SRs | 11 | 114 | 189 (133 used statistical synthesis methods) | 89 (25 assessed in detail) | 23 (diagnostic/prognostic SRs among 300 SRs identified) | 236 | 760
Selection criteria | All inclusive; meta-analysis of test accuracy as primary focus. | All inclusive | All inclusive | Cancer diagnosis; included SRs regardless of the use of quantitative synthesis methods. Screening tests + tests for risk factors were excluded; computer decision tools were also excluded. | All inclusive | All inclusive; reviews had to have searched ≥2 databases, stated search terms and inclusion criteria, and used a statistical method to summarize test accuracy. | All inclusive; reviews had to have used a statistical method to summarize test accuracy. Excluded HTAs, Cochrane reviews and AHRQ EPC reports.
Years covered | Jan 1990 – Dec 1991 | 1995 – 2001 | Up to 2002 | 1990 – 2003 | November 2004 | Up to 2008 | 1966 – 2009
Databases searched | MEDLINE, experts, bibliographies of retrieved papers | DARE | DARE (update of the search used in Whiting et al.33) | MEDLINE, Embase, MEDION, Cancerlit, HTA, DARE, Cochrane Database of Systematic Reviews | MEDLINE | MEDLINE, Embase, CINAHL, Cochrane Library, PsychInfo, Global health, HMIC, AMED | MEDLINE, bibliographies of papers and relevant reviews
Items extracted | Literature review methods; data extraction and presentation; statistical analysis methods. | Quality assessment methods. | Systematic review methods; statistical analysis and reporting; trends over time in statistical method use. | Objectives and setting of the SRs; participant characteristics. In the 25 studies assessed in detail: quality assessment methods; whether meta-analysis was performed; reporting of results; availability of data for reanalysis. | Basic reporting characteristics of reviews (bibliometric features, outcomes considered, whether any quantitative method was used). | Statistical and quality assessment methods; settings of test use; trends over time in statistical method use. | Literature search and study selection methods; quality assessment methods; statistical analyses and reporting methods; trends over time in multiple aspects of the review process, statistical analysis and reporting; availability of data for re-analysis.
Main findings | 2 of 11 studies reported the complete search strategy; all studies analyzed sensitivity and specificity, 2 studies used the sROC method and 2 did not provide a summary estimate; 6 of 11 studies discussed variability in reference standards; 7 studies reported comparisons between 2 or more index tests. | 49% of SRs had not conducted quality assessment; in most cases information on quality was incorporated in narrative synthesis; 13% of reviews used quality as an inclusion criterion. | 70% of SRs used quantitative methods; 52% used MEDLINE as the only source; 69% performed quality assessment; median number of studies=18; 68% of SRs do not report tests for heterogeneity (58% of those using statistical analyses); naïve pooling has decreased over time. | 75% of SRs stated inclusion criteria, 40% reported details of study design, 17% reported on the clinical setting, 17% reported on disease severity, 49% reported on tumor stage. Of the 25 reviews assessed in detail, 56% reported sensitivity, specificity, and sample sizes for individual studies. Of the 89 reviews, 61% attempted to formally synthesize results of the studies and 32% reported formal assessments of study quality. | No SRs were updates of previous reviews; harms were considered in 54% and costs in 35% of the reviews were this information was considered relevant; median number of included studies=39; quantitative synthesis was performed in 48% of SRs. | 27% of SRs used advanced statistical methods (BREM or hsROC); between 2006 and 2008 QUADAS was used in 40% of the studies; imaging tests are the most commonly assessed test category; 80% of tests are normally used in specialist settings. | As detailed in this report.

Studies are listed chronologically, based on the dates covered by their searches.

AHRQ = Agency for Healthcare Research and Quality; AMED = Allied and Complementary Medicine database; BREM = bivariate random effects meta-analysis; CINAHL = Cumulative Index to Nursing and Allied Health Literature; DARE = Database of Reviews of Effects; EPC = Evidence-based Practice Center; HMIC = Health Management Information Consortium database; hsROC = hierarchical summary receiver operating characteristic meta-analysis method; HTAs = health technology assessments; QUADAS = Quality Assessment of Diagnostic Accuracy Studies; SR = systematic review; sROC = summary receiver operating characteristic method

We also found that many aspects of the methods and reporting of systematic reviews of medical test accuracy have improved over time. Searching of multiple electronic databases without language restrictions has become more common; quality items such as verification bias, spectrum bias and blinding have been increasingly been considered in quality appraisal; and advanced statistical methods that simultaneously model sensitivity and specificity are beginning to be adopted. Empirical studies comparing the reporting of methodological quality items have documented an increase in the clarity of reporting of quality items in systematic reviews of therapeutic interventions36 after the International Committee of Medical Journal Editors endorsed the Quality of Reporting of Meta-analyses (QUOROM) checklist, compared to before. Similar data exist on the impact of the Consolidated Standards of Reporting Trials (CONSORT) statement37,38 for reporting of randomized trials.39,40 We observed that the QUADAS tool19,21 and quality items developed based on the STARD reporting checklist22,23 were used more often by recent systematic reviews; we hypothesize that their use may have had a similar influence on the reporting of meta-analyses of test accuracy.

A recent focused empirical assessment11 of meta-analyses of medical tests concluded that the increased use of bivariate random effects statistical models for sensitivity and specificity coincided with the development of easy-to-use routines for performing such analyses (e.g., the metandi and midas commands in Stata or scripts for SAS programming).41,42 We observed the same pattern. Further, we observed that, at the same time, the use of simpler, but less appropriate methods such as the fixed effects SROC model of Moses and Littenberg13,27 (which accounts for only part of the uncertainty in the bivariate probability model), has decreased. Guidance within the AHRQ Evidence-based Practice Center Program^c^ and the Cochrane Collaboration^d^ supports the use of hierarchical modeling methods in meta-analyses of test accuracy. Although such models are more theoretically motivated compared to separate univariate analyses of sensitivity and specificity for the binary classification case, their judicious application requires an understanding of the underlying model assumptions.43

c Available at: www.effectivehealthcare.ahrq.gov/tasks/sites/ehc/assets/File/methods_guide_for_medical_tests.pdf; accessed December 27, 2011.

d Available at: http://srdta.cochrane.org/handbook-dta-reviews; accessed December 27^th^, 2011.

We found substantial differences in methods and reporting of test accuracy studies across different types of medical tests. These differences may reflect either heterogeneous diffusion of methodological advances between research groups focusing on specific test types, or the reviewers' assessment that specific methodological approaches are not applicable to specific test types. In contrast, we found few differences in comparisons across different medical fields. Differences in some reporting or methodological characteristics of reviews correlated with the impact factor of journals where they were published and the number of citations they accrued over time. Interpretation of these differences is challenging, given the large number of comparisons performed and the possibility that journal editorial policies and journal readability could confound many of the observed associations.

Our work has several limitations that need to be considered when interpreting our results. First, we relied on searches using methodological filters for identifying reports of meta-analyses of medical test accuracy studies and we only considered English language publications.44 Also, we relied exclusively on MEDLINE searches, supplemented by screening of the reference lists of eligible studies and those of relevant review articles, to identify eligible reviews. More comprehensive searches would have required the examination of a much larger number of abstracts with little expected incremental yield. Second, we focused on meta-analyses using aggregate published data and excluded individual patient data analyses. Although the latter represent a minority of all published meta-analyses they provide additional flexibility in exploring between-study heterogeneity due to patient level factors.45 Third, we did not perform double extraction for all eligible studies. However, we implemented several procedures for standardizing the definition of the extracted variables during data extraction and performed extensive quality control of the final dataset. Further, a substantial proportion of eligible articles were extracted in duplicate.

This comprehensive overview of meta-analyses of test accuracy highlights the current status and the temporal evolution of a complex research field. Available meta-analyses of medical tests have several limitations in regards to methodological approaches and reporting characteristics; however, over time reviews have increasingly performed more comprehensive assessments of study quality and have used more appropriate statistical methods addressing the particular challenges relevant to reviews of test accuracy. Based on our review of the literature, and observations from this current empirical assessment, we identify some cross-cutting methodological issues relevant to meta-analytic practice in Box 2. Areas for potential future methodological research include the assessment of publication and reporting bias in reviews of test accuracy, the collection of empirical evidence on how study-level characteristics can influence the results of systematic reviews, quantitative methods for the comparative assessment of multiple alternative index tests, and the evaluation of modeling approaches for contextualizing the findings of reviews of test accuracy.

Box 2 Cross-cutting methodological issues relevant to meta-analytic practice

- Comparative effectiveness reviews of medical tests48
  - Often many alternative tests are applicable to a given testing scenario; systematic reviews may want to consider all relevant index tests that are applicable to the population and disease of interest.
  - In cases where multiple index tests are applicable, reviews that directly compare test performance may have the greatest impact on clinical practice.
- Defining the setting and role of test use
  - The findings of systematic reviews can be meaningfully applied to clinical practice only if the role (add-on, triage, replacement) and setting (screening, diagnosis, prognosis/prediction, treatment selection) of test use is explicitly considered. These aspects of test use have implications for the study designs to be considered, the information to be extracted from each eligible study, the interpretation of individual study results, and the synthesis of findings across studies.49
- Methods and reporting of systematic reviews of test performance50-53
  - A priori defined protocols, clearly delineating the scope of the review and outlining the proposed methods is in accordance with commonly held standards of research conduct, and probably applies to systematic reviews as much as other research enterprises.
  - Explicitly reporting the methodological approach followed by systematic reviews (including any deviations from the review protocol) promotes clarity. It is probably good practice for reviewers to consult existing (and continuously evolving) guidance on the optimal methods for searching the literature, identifying and selecting relevant studies, extracting data, assessing the validity of included studies, qualitatively and quantitatively synthesizing study results.
  - The assessment of study “quality” or “risk of bias” is an important component of systematic reviews of medical tests – yet exactly how these assessments (should) affect the conclusions of the systematic review is still a matter of research.
- Examining the applicability of review findings and transferability of estimates
  - Based on our empirical assessment, many reviews did not adequately describe whether the applicability of research findings from individual studies was assessed, and if yes, how. Information for the assessment of applicability includes, but is not limited to, details about the index and reference standard tests used, and the demographics and disease-related characteristics of the population enrolled in each study. Assessment of applicability is critical in contextualizing the conclusions of a systematic review.
- Interpreting and contextualizing review results
  - Reviews of test accuracy address an intermediate component of the effect of tests on clinical outcomes.54 Although studies assessing the overarching question of test effectiveness on clinical outcomes are rare, reviews of test performance often can only provide part of the information needed to fully assess the impact of tests.55 Other intermediate outcomes that could be considered include the impact of test results on physicians' diagnostic thinking, and on therapeutic decisionmaking.56
  - In the absence of studies assessing the direct effect of tests on clinical outcomes, formal modeling or simple (“back-of-the-envelope”) projections of the potential impact of tests may be informative.57

The large and rapidly expanding number of available meta-analyses identified by this overview reflects the growing interest in “evidence-based diagnosis”.46,47 Increasing use of quality checklists is expected to facilitate further improvements in the quality assessment of primary studies included in meta-analyses of medical tests. Similarly, increasing diffusion of methodological advances, availability of software to perform advanced statistical analyses and clear guidelines for the conduct and reporting of meta-analyses of test accuracy will hopefully lead to further improvements in the practice of systematic reviews of medical tests.